# DATA GAPS

Mental Health, United States, 2010 compiles estimates from multiple and disparate data sources to serve as a comprehensive, up-to-date reference source on the Nation's mental health. This section notes the key gaps in the estimates that may help delineate potential areas for further study.

Despite the strengths of the data sources in this volume, they are limited in their ability to serve as a public health surveillance system that can track over time the U.S. population's overall mental health status; capacity of, access to, and receipt of treatment; and the degree to which the need for treatment is met. At its best, a robust mental health surveillance system would provide information within subregions (States, counties, or rural/metropolitan area) of the United States. Such data could be used, for example, to track the impact of natural disasters on populations' mental health status, as well as the ongoing mental health of particular subpopulations, such as children and older adults. Public health surveillance systems that exist for other diseases, such as HIV/AIDS, could serve as examples for mental health.

As part of, or in addition to, performing a mental health surveillance function, data are needed over the course of peoples' lives to help monitor recovery from and the course of mental illness. Mental health conditions often are long-lasting and have symptoms that greatly impair a person's ability to function in daily life. Studies that compare, for example, depression to other long-lasting and recurrent chronic diseases, such as arthritis, asthma, and diabetes, show that depression is associated with one of the greatest decrements to health (Moussavi, Chatterji, Verdes, Tandon, Patel, & Ustun, 2007). Data are needed to monitor and track mental illness from the onset of a person's symptoms through the period of recovery. Severity, acuity, and functioning are critical determinants of what resources would be needed to address mental health conditions. Thus, data would ideally contain measures of diagnosis or class of disease and reliable indicators of disease severity and acuity and/or a person's functioning. Were such surveillance data available, they could help the Substance Abuse and Mental Health Services Administration (SAMHSA) achieve one of its eight strategic initiatives: to support recovery from mental illness.

Surveillance data are particularly needed for people in vulnerable subpopulations, many of which have higher rates of mental health conditions. No reliable national- or subnational-level data are available to monitor the mental health of children, people who are homeless, and military families. Data for other subgroups may be old and infrequently available. This is compounded by the fact that data on people in institutional settings—such as those who are incarcerated or in nursing homes—are often excluded from the sampling frame of large-scale surveys, such as the National Survey on Drug Use and Health (NSDUH). Ongoing efforts, such as a forthcoming survey of inmates, seek to rectify this.

Data on gaps in treatment capacity for specific mental health services and supports, as well as for specific population groups (e.g., children, older adults, returning military, persons in jails and prisons, persons with major depression), are important for ensuring that the appropriate mix and level of services and supports are available where they are needed. Assessing gaps in capacity entails collecting data on treatment need and treatment receipt and then combining these data. Over the next several years, health care reform will greatly expand health insurance coverage for many currently uninsured individuals. However, expanding insurance eligibility for individuals with mental illnesses may have limited impact if Federal, State, and local mental health systems are unable to estimate future demand appropriately and identify and expand capacity to eliminate gaps in treatment capacity.

The increase in demand for the mental health treatment system that will arise from health care reform also raises questions about the degree to which the mental health workforce can meet the increased demand. No single data source exists for such workforce data. Rather, separate data sets are available for each provider type that vary by the measures they contain, the frequency of data collection, and the methods of data collection. Some use membership surveys (thereby missing nonmembers and nonresponders), whereas others use licensure data (which may include professionals who are working part time or not clinically active). Despite occasional comprehensive analyses that unify these various data sets, there is no program to systematically collect data over time, as would be required for consistent monitoring.

In 2005, Medicaid accounted for 28 percent of all mental health spending (SAMHSA, 2010). The expanded demand for mental health services from health care reform means that Medicaid will take an even greater role in underwriting mental health treatment. However, national and regularly updated estimates of detailed Medicaid mental health spending using these data are not available. The preferred data for tracking spending and health care use in Medicaid are on claims filed for reimbursement. The Centers for Medicare & Medicaid Services makes these data available for analysis. But there are several challenges to obtaining reliable estimates from these available data. Chief among them is that most States place the majority of Medicaid beneficiaries in managed care, and reliable estimates on utilization and spending are typically not available for Medicaid managed care beneficiaries.

Another issue concerning obtaining reliable estimates from existing data is that estimates of the amount of mental health care being provided by nonspecialty physicians, such as primary care physicians, typically depend on a mental health diagnosis being recorded in the medical chart or billing record. However, analyses have shown that even though primary care physicians write the majority of prescriptions for psychotropic medications, these prescriptions are not accompanied by a mental health diagnosis. Thus, spending on mental health treatment provided by primary care physicians may be underestimated in current estimates. Better data are needed on how to allocate expenditures to primary care physician visits when a psychotropic medication is provided.

Addressing any one of the above data gaps may require considerable coordination among data providers, such as Federal agencies. For example, data on military families' behavioral health needs may require collaboration among SAMHSA, the U.S. Department of Veterans Affairs (VA), and the Department of Defense. The gaps may need to be addressed so that policy and treatment provision can keep pace with the changing face of the U.S. mental health service delivery system. In a period of considerable financial strain on taxpayer-supported services and system-wide health care reform, good data are critical to making informed and timely decisions on the provision of scarce mental health resources.

## 6.1 References

Moussavi S, Chatterji S, Verdes E, Tandon A, Patel V, Ustun B. September. Depression, chronic diseases, and decrements in health: Results from the World Health Surveys. The Lancet. 2007;370(9590):851-858. [doi: 10.1016/S0140-6736(07)61415-9].
Substance Abuse and Mental Health Services Administration (SAMHSA). 2010. National expenditures for mental health services and substance abuse treatment, 1986–2005. (DHHS Publication No. SMA 10-4612). Rockville, MD. Center for Mental Health Services and Center for Substance Abuse Treatment, SAMHSA.