# STATES: PEOPLE, PROVIDERS, AND PAYERS

## 5.1 Narrative

### 5.1.1 Overview

States play an important role in helping monitor mental health indicators and prioritizing and providing treatment. In 2005, public sources funded $66 billion in mental health spending, which was 58 percent of all mental health care spending. About half of that public spending—nearly $34 billion—was spent by States (see Tables 73 and 75 in Section 7). These findings, together with the fact that much of the legislation on mental health treatment is written by State governments, indicates that State-level estimates are critical to a comprehensive view of mental health in the United States.

This section is organized similarly to the three previous sections and includes, in the following order, the number and characteristics of people with mental illness (people), the number and types of mental health facilities and practitioners (providers), and expenditures for mental health services (payers). The data presented support the Substance Abuse and Mental Health Services Administration (SAMHSA) in one of its eight strategic initiatives, Data, Outcomes, and Quality, by improving the accessibility of mental health prevalence, capacity, and expenditures data for provider staff, stakeholders, funders, and policy makers in need of State-level estimates (SAMHSA, 2011).

### 5.1.2 Mental Health of States' Populations

(Exhibits 21, 22, and 23 and Tables 98 through 102)

The exhibits in this subsection map State-level estimates of key mental health–related indicators. For each exhibit, the corresponding data table in Section 7 (indicated in the exhibit note) was used to place each State into one of five ranked categories from highest to lowest. Although the text describes and summarizes each exhibit, further study may be needed to interpret any State-to-State variation in the estimates.

Data on the mental health of State populations describe the number of people with any mental illness (AMI), the subgroup with serious mental illness (SMI), and the number of people with major depressive episode (MDE). Data on adults are presented in Exhibits 21 and 22 and Tables 98 and 99, and data on youth are presented in Exhibit 23 and Table 100. Monitoring the number of people with SMI is important because SMI is particularly debilitating and interferes with a person's ability to cope in everyday situations. MDE is defined as a 2-week period during the year when a person experiences depressed mood. Monitoring MDE is important because MDE is one of the components of major depression, which is one of the most common mental illness diagnoses.

The main findings for the exhibits and tables indicate that there was little variation across States in the rates of past year SMI (a range of 3.7 percentage points) or MDE (a range of 4.3 percentage points) for adults or in the rate of past year MDE for youth (a range of 3.5 percentage points). To obtain statistically accurate estimates at the State level for these data, two years of data were combined. Thus, the estimates for SMI and MDE span the years 2008 to 2009.

Suicide prevention remains an important concern for State policy makers. Key to supporting this prevention activity is monitoring the rate of death by suicide. In 2006, suicide was the 11th leading cause of death in the United States (Heron, Hoyert, Murphy, Xu, Kochanek, & Tejada-Vera, 2009). As seen in Table 101, national death rates by suicide have increased slightly from 2005 to 2007 (from 10.9 percent to 11.3 percent). In 2007, the rates across States ranged from 5.8 percent to 22.1 percent.

Receipt of mental health treatment is more common among certain subpopulations. Rates of mental illness in the inmate population are understood to be particularly high, and in a time of tight State budgets, this is of particular concern to State policy makers who must find a way to fund treatment. In 2000, 12.8 percent of total inmates (over 137,000 inmates) received therapy and counseling, which was the most common form of mental health service received (Table 102). There is a large range, between 2.7 percent and 37.3 percent, for the receipt of this service across States in 2000.

### 5.1.3 Providers and Settings for Mental Health Services at the State Level

(Exhibits 24, 25, 26, and 27 and Tables 103 through 118)

Mental health treatment relies on specialist care (from psychiatrists, for example) and nonspecialist care (from primary care providers, for example); much of the care is delivered in an outpatient setting. Tables 103 and 104 present estimates on adults receiving outpatient specialty and nonspecialty mental health treatment. To provide statistically reliable estimates at the State level, data from 5 years (2005–2009) are combined. Over those years, the percentage of adults receiving treatment from outpatient specialty providers ranged from 3.0 to 9.5 percent. The percentage of adults receiving mental health treatment from outpatient nonspecialty providers ranged from 1.1 to 3.7 percent.

Table 106 presents treatment receipt estimates for youth aged 12 to 17 for the period 2005 to 2009 combined. Data from 5 years are combined to provide statistically reliable estimates at the State level. Nationwide, 11.4 percent of youth (2.9 million youth) received treatment from outpatient specialty providers, and rates across States ranged from 8.0 to 16.9 percent. Nationally, 2.8 percent of youth aged 12 to 17 (over 700,000 youth) received treatment from providers who were not mental health specialists (a medical pediatrician or other family doctor), and State-level estimates ranged from 1.5 to 4.5 percent.

State-level estimates for the number of mental health organizations and service capacity vary considerably, with States that have a greater proportion of the population living in rural areas often having lower capacity. Table 109 presents estimates of the number of mental health professionals across disciplines. The District of Columbia and Maryland—with relatively high proportions of the population living in urban areas—have the highest rates of mental health professionals. States with large proportions of the population living in rural areas, such as Mississippi and Nevada, often have the lowest rates, although the rates vary by discipline. An important limitation of these data is that they do not distinguish between adult and child service providers.

Exhibit 26 and Table 111 present estimates on the shortage of mental health professionals in the adult household population across all States. Overall, many northeast States (Connecticut, the District of Columbia, Maryland, Massachusetts, New Hampshire, and New York) do not appear to be facing a shortage of professionals. States facing a shortage, such as Alabama, Idaho, Mississippi, Nevada, and Wyoming, have a relatively large proportion of the population living in rural areas. The supply of inpatient psychiatric beds in U.S. hospitals also varies across States, as illustrated in Tables 113, 114, and 115, and in Exhibit 27. The most populated States in the country (California, New York, and Texas) had the most inpatient psychiatric beds (Federal and non-Federal) relative to all States, whereas the District of Columbia, Mississippi, and Wyoming had the highest number of these beds per 100,000 adults (Exhibit 27 and Table 115). The total number of mental health organizations within States varies widely, with less populated States and States with a relatively large proportion of the population living in rural areas having fewer facilities, as seen in Tables 116, 117, and 118. Nationwide, the most common forms of mental health organizations are outpatient clinics and general hospitals that treat psychiatric patients.

### 5.1.4 States' Payers and Payment Mechanisms

(Tables 119 through 132)

Mental health spending from all public and private sources totaled almost $113 billion in 2005 (see Table 70). Thirty percent of that spending comes from State sources (see Table 75). State Mental Health Agencies (SMHAs) have considerable authority in directing State mental health treatment resources. SMHA revenues are derived from State general funds, followed by Medicaid and the State block grant programs, as seen in Table 119. In fiscal year (FY) 2008, 44 of 51 SMHAs devoted at least half of their funding to community mental health programs (Table 120).

The recent recession has particularly affected State budgets, leading to concern about how States can support people with mental health conditions. Approximately two thirds of States have cut mental health care funding in the past 3 years, with total cuts reaching nearly $1.6 billion (Honberg, Diehl, Kimball, Gruttadaro, & Fitzpatrick, 2011). Furthermore, mental health spending grew at a slower rate than the national gross domestic product in 2004 and 2005, and it continued to shrink as a share of all health spending (Mark et al., 2011; SAMHSA, 2011). Tables 121 and 122 describe the impact for SMHAs across the Nation in terms of funding and the decline in the number of inpatient State psychiatric beds. The South Atlantic region experienced the largest percentage of budget cuts in FY 2009, FY 2010, and FY 2011 (Table 121). Nationwide, approximately 2,200 inpatient State psychiatric beds were closed in 2010 (Table 122). Further study may be needed to determine the potential impact of closing psychiatric beds on the provision of care.

One of the main sources of funding for mental health treatment in States is Medicaid, a program funded by the Federal and State governments and administered by the States. It provides funding for low-income individuals and others in certain defined eligibility categories to receive health coverage, including treatment for mental health conditions. Of the $113 billion spent on mental health nationwide, 28 percent of the spending was through Medicaid (see Table 64). Spending by Medicaid programs across 13 States can be seen in Tables 123 through 127. The most common diagnostic category covered by Medicaid across all 13 States in 2003 was neurotic and other depressive disorders (over 280,000 beneficiaries), followed by major depression (over 254,000 beneficiaries), and all other diagnoses (over 234,000 beneficiaries) (Table 124).

Another source of funding for mental health treatment is the Federal Medicare program, which provides coverage to people aged 65 or older or those who qualify because of a disability. Medicare has received considerable attention from policy makers because it accounts for 23 percent of all health care spending and about half of health spending paid for by the government (National Center for Health Statistics, 2011). For mental health, Medicare is an important but relatively small share of spending at about 8 percent (see Exhibit 18 and Table 75). Tables 128 through 132 provide data on Medicare spending. In 2007, more than $8 billion of Medicare funds were spent on mental health and substance abuse treatment units in community hospitals nationwide. Medicare mental health expenditures per claimant were on average $1,500 but also varied across the States (Table 129).

## 5.2 Exhibits

Exhibits 21–27

### Adults with Serious Mental Illness

In the 2008–2009 period, State-specific prevalence of adults with past year serious mental illness ranged from 3.5 percent to 7.2 percent.

Serious mental illness (SMI) is of particular concern to policy makers and providers because having this kind of diagnosable mental illness involves serious functional impairment that can greatly diminish a person's quality of life. Since 2008, the annual National Survey on Drug Use and Health (NSDUH) has included measures that permit the estimation of SMI in adults across the United States. Exhibit 21 uses two years of data combined (2008 and 2009) to display geographic variation across the States in the proportion of adults with past year SMI. The two years of data were combined to achieve statistically precise estimates. The exhibit shows the following patterns:

■ During the 2008–2009 period, State-specific variation in the proportion of people with SMI ranged from 3.47 percent to 7.20 percent. Because State-to-State variation in the rate of SMI was low, the five categories have a small range of values, of about 0.7 of a percentage point. Two States were in the category corresponding with the highest State-specific prevalence of SMI (6.45 to 7.20 percent): Arkansas and Rhode Island.
■ Four States were in the second highest category (5.71 to 6.44 percent): Idaho, Indiana, Utah, and West Virginia.
■ The remaining 44 States and the District of Columbia were fairly evenly spread across the third highest (4.96 to 5.70 percent), fourth highest (4.21 to 4.95 percent), and lowest (3.47 to 4.20 percent) categories.
■ The States in the lowest category of State-specific prevalence (3.47 to 4.20 percent) are along the East Coast, as well as Alaska, Hawaii, Mississippi, North Dakota, and South Dakota.

Exhibit 21 Percentage of persons aged 18 or older with past year serious mental illness (SMI), by State, 2008–2009

NOTES: Serious mental illness (SMI) is defined as having a diagnosable mental, behavioral, or emotional disorder, other than a substance use disorder, that met the criteria in the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) (APA, 1994) and resulted in serious functional impairment. Each State was placed into one of five categories that range from highest to lowest SMI. Category cutoffs were created by taking the difference between the values for the highest and lowest ranked States and then dividing that difference by five. See Table 98 for more details on the constructs in this exhibit.

SOURCE: National Survey on Drug Use and Health, 2008 and 2009, Substance Abuse and Mental Health Services Administration, Office of Applied Studies.

Exhibit 21 is a map showing the percentage of persons aged 18 or older with past year serious mental illness (SMI) by state from 2008 to 2009. The accessible table for this exhibit is located in Section 7, Table 98.

### Adults with Past Year Major Depressive Episode

In the 2008–2009 period, State-level prevalence rates of adults with a past year major depressive episode ranged from 5.2 percent to 9.5 percent.

Major depressive disorder is a serious and relatively common mental health condition that can greatly reduce a person's ability to function in life. One important component of this disorder is major depressive episode (MDE), which is a 2-week period over which a person experiences depressed mood. To assess the mental illness of the Nation, the National Survey on Drug Use and Health (NSDUH), a nationally representative survey of the civilian, noninstitutionalized population of the United States, asks questions pertaining to incidence of past year MDE among adults and youth in the United States. Exhibit 22 displays the geographic variation in the proportion of adults with past year MDE in 2008 and 2009 (two years of data were combined to obtain statistically precise estimates). The exhibit shows the following:

■ State-specific prevalence of adults with past year MDE ranged from 5.20 percent to 9.46 percent.
■ There was little variation in past year MDE across the States. Thus, the five categories have a small range of values of about 0.9 of a percentage point.
■ One State (Rhode Island) was in the category corresponding with the highest State-specific prevalence of MDE (8.61 to 9.46 percent).
■ Two States (Arkansas and Indiana) were in the second highest MDE category (7.76 to 8.60 percent).
■ A relatively large number of States were in each of the remaining three categories; 15 States were in the third highest category (6.91 to 7.75 percent); 21 States were in the fourth highest category (6.05 to 6.90 percent); and 11 States, plus the District of Columbia, were in the lowest category (5.20 to 6.04 percent).

Exhibit 22 Percentage of persons aged 18 or older with past year major depressive episode (MDE), by State, 2008–2009

NOTES: Major depressive episode (MDE) is defined as a period of at least 2 weeks when a person experienced a depressed mood or loss of interest or pleasure in daily activities and had a majority of specified depression symptoms. Each State was placed into one of five categories that range from highest to lowest MDE. Category cutoffs were created by taking the difference between the values for the highest and lowest ranked States and then dividing that difference by five. See Table 99 for more details on the constructs in this exhibit.

SOURCE: National Survey on Drug Use and Health, 2008 and 2009, Substance Abuse and Mental Health Services Administration, Office of Applied Studies.

Exhibit 22 is a map showing the percentage of persons aged 18 or older with past year major depressive episode (MDE) by state from 2008 to 2009. The accessible table for this exhibit located in Section 7, Table 99.

### Youth with Past Year Major Depressive Episode

In the 2008–2009 period, State-level prevalence rates of youth with a past year major depressive episode ranged from 6.8 percent to 10.3 percent.

Depression involves many troubling symptoms, including persistent sadness, discouragement, diminished feelings of self-worth, and loss of interest in usual activities. Each year, depression affects millions of adolescents. One aspect of depression is having a major depressive episode (MDE), a period of 2 weeks or longer during which certain symptoms are experienced. The National Survey on Drug Use and Health (NSDUH), a nationally representative survey of the civilian, noninstitutionalized population of the United States, reports State-level estimates of past year MDE among youth. Exhibit 23 shows the geographic dispersion by State of past year MDE among youth aged 12 to 17 in 2008 and 2009 (two years of data were combined to ensure statistically precise estimates). The exhibit shows the following:

■ The State-specific prevalence of youth with MDE ranged from 6.75 percent to 10.28 percent.
■ There was relatively little variation in past year MDE across the States. Thus, the five categories have a small range of values of about 0.7 of a percentage point.
■ One State (Oregon) was in the category corresponding to the highest State-specific prevalence of past year MDE for youth (9.57 to 10.28 percent).
■ Seven States were in the lowest MDE category for youth (6.75 to 7.45 percent): the District of Columbia, Maryland, Mississippi, Nevada, New Jersey, Pennsylvania, and Texas.
■ The middle three categories of past year MDE prevalence among youth had roughly equivalent numbers (14 to 15) of States in each category.

Exhibit 23 Percentage of persons aged 12 to 17 with a past year major depressive episode (MDE), by State, 2008–2009

NOTES: Major depressive episode (MDE) is defined as a period of at least 2 weeks when a person experienced a depressed mood or loss of interest or pleasure in daily activities and had a majority of specified depression symptoms. Each State was placed into one of five categories that range from highest to lowest MDE. Category cutoffs were created by taking the difference between the values for the highest and lowest ranked States and then dividing that difference by five. See Table 100 for more details on the constructs in this exhibit.

SOURCE: National Survey on Drug Use and Health, 2008 and 2009, Substance Abuse and Mental Health Services Administration, Office of Applied Studies.

Exhibit 23 is a map showing the percentage of persons aged 12 to 17 with past year major depressive episode by state from 2008 to 2009. The accessible table for this exhibit located in Section 7, Table 100.

### Adults Using Outpatient Specialty Mental Health Treatment

In the 2005–2009 period, State-level utilization rates of outpatient specialty mental health treatment for adults ranged from 3.0 percent to 9.5 percent.

A number of specialist professionals provide important services to people with mental health symptoms. These specialists include psychologists, psychiatrists, therapists, counselors, and social workers. Except for when treatment requires an overnight stay in inpatient or residential settings, specialists typically provide treatment to patients in an outpatient setting, such as a clinic, office, or day hospital. The National Survey on Drug Use and Health (NSDUH) reports State-level utilization rates for several types of mental health treatment. Exhibit 24 shows the State utilization rates for receiving any outpatient specialty mental health treatment in the 5-year period from 2005 through 2009. Five years of data were combined to ensure statistically precise estimates. The exhibit shows the following:

■ The highest State-level utilization rate of outpatient mental health treatment for adults was 9.5 percent, which was more than three times the lowest rate of 3.0 percent. This range is high compared with the variation in mental health prevalence across States.
■ Two States were in the highest category of treatment utilization: the District of Columbia and Rhode Island. A cluster of States in the Northeast was in the second highest category of utilization.
■ Although the overall range in rate of receipt across all States was relatively large, the majority of States (36 of 51 examined) were fairly evenly spread across two categories. Thus, for a large subset of States, the range of estimates was low.
■ Twenty-four States were in the second lowest category, for which the utilization rate was between 4.32 and 5.62 percent. These States were spread across the country, excluding the Northeast and much of the Southeast.
■ Twelve States were in the lowest category. These States were all in the South and Southeast, plus Hawaii and South Dakota.

Exhibit 24 Percentage of persons aged 18 or older who received outpatient specialty mental health treatment, by State, 2005–2009

NOTES: Each State was placed into one of five categories that range from highest to lowest proportion of the population who received treatment. Category cutoffs were created by taking the difference between the values for the highest and lowest ranked States and then dividing that difference by five. See Table 103 for more details on the constructs in this exhibit.

SOURCE: National Survey on Drug Use and Health, 2005–2009, Substance Abuse and Mental Health Services Administration, Office of Applied Studies.

Exhibit 24 is a map showing the percentage of persons aged 18 or older who received outpatient specialty mental health treatment by state from 2005 to 2009. The accessible table for this exhibit located in Section 7, Table 103.

### Youth Using Outpatient Specialty Mental Health Treatment

In the period 2005–2009, the State-level rates of youth using past outpatient mental health treatment was between 8.0 and 16.9 percent.

The mental health treatment that youth use most often is outpatient treatment. The National Survey on Drug Use and Health (NSDUH) reports State-level utilization rates for outpatient specialty treatment by youth aged 12 to 17. This survey defines outpatient treatment as any treatment or counseling received at an outpatient mental health clinic or center; the office of a private therapist, psychologist, psychiatrist, social worker, or counselor that was not part of a clinic; a doctor's office that was not part of a clinic; an outpatient medical clinic; a partial day hospital or day treatment program; or some other place. Exhibit 25 shows geographic variation of these estimates in the 5-year period from 2005 through 2009 (five years of data were combined to ensure statistically precise estimates). The exhibit shows the following:

■ The proportion of youth in a State who used outpatient mental health treatment ranged from 8.00 to 16.90 percent.
■ There was relatively little variation in the proportion of youth who used outpatient mental health treatment across the States. Thus, the five categories have a small range of values, of about 1.8 percentage points.
■ The number of States in each category was uneven. Two States (New Hampshire and Vermont) were in the highest category (15.12 to 16.90 percent), and 6 States (Alaska, Georgia, Louisiana, Mississippi, Nevada, and Texas) were in the lowest category (8.00 to 9.77 percent).
■ Nine States were in the second highest category (13.34 to 15.11 percent), 18 States were in the middle category (11.56 to 13.33 percent), and 16 States were in the second lowest category (9.78 to 11.55 percent).

Exhibit 25 Percentage of persons aged 12 to 17 who received outpatient specialty mental health treatment, by State, 2005–2009

NOTES: Each State was placed into one of five categories that range from highest to lowest proportion of the population who received treatment. Category cutoffs were created by taking the difference between the values for the highest and lowest ranked States and then dividing that difference by five. See Table 106 for more details on the constructs in this exhibit.

SOURCE: National Survey on Drug Use and Health, 2005–2009, Substance Abuse and Mental Health Services Administration, Office of Applied Studies.

Exhibit 25 is a map showing the percentage of persons aged 12 to 17 who received outpatient specialty mental health treatment by state from 2005 to 2009. The accessible table for this exhibit located in Section 7, Table 106.

### Shortage of Mental Health Professionals in the United States, 2006

In 2006, the proportion of individuals facing a shortage of mental health professionals ranged from 0.0 to 31.6 percent across the States.

Recently published research has shown that counties with a relatively large rural population may be more likely to have a shortage of mental health professionals (Ellis et al., 2009; Konrad et al., 2009; Thomas et al., 2009, 2010). Exhibit 26 describes State-level variation in the shortage of mental health professionals. The exhibit shows the following:

■ In general, States with a large proportion of the population living in rural areas had a greater shortage of mental health professionals.
■ Thirty-three States were in the two highest categories, with 18 States in the highest category (25.28 to 31.59 percent) and 15 States in the second highest category (18.96 to 25.27 percent).
■ The Northeast has relatively low rates of shortage, perhaps because a large proportion of each State's population is urban. Thirteen of the 15 States in the two lowest categories are in the Northeast. California and Hawaii are also in the second lowest category (6.32 to 12.63 percent).

Exhibit 26 Estimated shortage of mental health professionals in the United States, by State, 2006

NOTES: Each State was placed into one of five categories that range from highest to lowest proportion of the population facing a shortage of mental health professionals. Category cutoffs were created by taking the difference between the values for the highest and lowest ranked States and then dividing that difference by five. See Table 111 for details of how the shortage measures were developed.

SOURCES: Ellis, A. R., Konrad, T. R., Thomas, K. C., & Morrissey, J. P. (2009). County-level estimates of mental health professional supply in the United States. Psychiatric Services, 60(10), 1315–1322.

Konrad, T. R., Ellis, A. R., Thomas, K. C., Holzer, C. E., & Morrissey, J. P. (2009). County-level estimates of need for mental health professionals in the United States. Psychiatric Services, 60(10), 1307–1314.

Thomas, K. C., Ellis, A. R., Konrad, T. R., Holzer, C. E., & Morrissey, J. P. (2009). County-level estimates of mental health professional shortage in the United States. Psychiatric Services, 60(10), 1323–1328.

Thomas, K. C., Ellis, A. R., & Morrissey, J. P. (2010). Where are the psychiatric physician assistants? Reply. Psychiatric Services, 61(1), 95–96.

Exhibit 26 is a map showing the estimated shortage of mental health professionals in United States, by state 2006. The accessible table for this exhibit located Section 7, Table 111.

### Non-Federal Inpatient Psychiatric Hospital Beds

In 2007, the number of non-Federal inpatient psychiatric hospital beds (per 100,000 adults) across all States and the District of Columbia ranged from 21.2 to 222.7.

People with serious symptoms of mental illness may need inpatient care. Among the types of facilities that can provide inpatient care, psychiatric hospitals are a particularly important source for specialist care. However, in an era of State budget crises and preferences for community-based treatment, psychiatric hospitals are closing and dedicated beds may no longer be as available (see Table 122). With a few exceptions, States and private sources rather than the Federal government fund most psychiatric hospitals. Exhibit 27 shows the geographic variation in the number of non-Federal inpatient psychiatric hospital beds per 100,000 adults across all States in 2007. The estimates are from Aron et al. (2009), who used the American Hospital Association's annual survey database for fiscal year 2007. That database has been maintained since 1946 to provide estimates on the structure, facilities, and services of the Nation's hospitals and health care providers. The exhibit shows the following:

■ The number of non-Federal inpatient psychiatric hospital beds across all States and the District of Columbia ranged from 21.22 to 222.72 per 100,000 adults.
■ Two States were in the top two categories with the highest number of beds per 100,000 adults: the District of Columbia and Mississippi (96.84 to 222.72 beds). New Jersey and New York were in the second highest category (77.93 to 96.83 beds).
■ Thirteen States, including all States on the West Coast of the United States, among others across the country, were in the category with the fewest number of beds (21.22 to 40.12 beds).

Exhibit 27 Inpatient psychiatric hospital beds in non-Federal hospitals, per 100,000 adults, by State, 2007

NOTES: Each State was placed into one of five categories that range from highest to lowest number of beds per 100,000 adults. Category cutoffs were created by taking the difference between the values for the highest and lowest ranked States and then dividing that difference by five. Because the District of Columbia had an outlier value, it was excluded from the threshold calculations but included in the exhibit. See Table 115 for more details on the constructs in this exhibit.

SOURCES: Aron, L., Honberg, R., Duckworth, K., Kimball, A., Edgar, E., Carolla, B., … & Fitzpatrick, M. (2009). Grading the States 2009: A report on America's health care system for adults with serious mental illness. Arlington, VA: National Alliance on Mental Illness.

State Single Year of Age and Sex Resident Population Estimates: April 1, 2000 to July 1, 2009, U.S. Census Bureau.

Exhibit 27 is a map showing the inpatient psychiatric hospital beds in non-Federal hospitals, per 100,000 adults, by state 2007. The accessible table for this exhibit located Section 7, Table 115.

## 5.3 References

American Psychiatric Association (APA). 1994. Diagnostic and statistical manual of mental disorders. 4th ed. Washington, DC. APA.
Aron L, Honberg R, Duckworth K, Kimball A, Edgar E, Carolla B, et al., Fitzpatrick M. 2009. Grading the States 2009: A report on America's health care system for adults with serious mental illness. Arlington, VA. National Alliance on Mental Illness.
Ellis AR, Konrad TR, Thomas KC, Morrissey JP. County-level estimates of mental health professional supply in the United States. Psychiatric Services. 2009;60(10):1315-1322. [pmid: 19797370].
Heron M, Hoyert DL, Murphy SL, Xu J, Kochanek KD, Tejada-Vera B. Deaths: Final data for 2006. National Vital Statistics Reports. 2009;57(14). Hyattsville, MD. National Center for Health Statistics.
Honberg R, Diehl S, Kimball A, Gruttadaro D, Fitzpatrick M. 2011. March. State mental health cuts: A national crisis. Arlington, VA. National Alliance on Mental Illness.
Konrad TR, Ellis AR, Thomas KC, Holzer CE, Morrissey JP. County-level estimates of need for mental health professionals in the United States. Psychiatric Services. 2009;60(10):1307-1314. [pmid: 19797369].
Mark TL, Levit KR, Vandivort-Warren R, Buck JA, Coffey RM. Changes in US spending on mental health and substance abuse treatment, 1986–2005, and implications for policy. Health Affairs. 2011;30(2):284-292. [pmid: 21289350].
National Center for Health Statistics. 2011. Health, United States, 2010: With special feature on death and dying. Hyattsville, MD. Centers for Disease Control and Prevention.
Substance Abuse and Mental Health Services Administration (SAMHSA). 2011. Leading change: A plan for SAMHSA's roles and actions 2011–2014. (DHHS Publication No. SMA 11-4629). Rockville, MD. SAMHSA.
Thomas KC, Ellis AR, Konrad TR, Holzer CE, Morrissey JP. County-level estimates of mental health professional shortage in the United States. Psychiatric Services. 2009;60(10):1323-1328. [pmid: 19797371].
Thomas KC, Ellis AR, Morrissey JP. Where are the psychiatric physician assistants? Reply. Psychiatric Services. 2010;61(1):95-96. [pmid: 20044428].