# PROVIDERS AND SETTINGS FOR MENTAL HEALTH SERVICES

## 3.1 Narrative

### 3.1.1 Overview

As documented previously, mental illness and its associated impairment may impose substantial burdens on individuals and families that could be reduced by effective treatment. This section provides information on mental health treatments available to adults and children in the United States and the extent to which these treatments are being used. Among the populations examined are those addressed by the Substance Abuse and Mental Health Services Administration's (SAMHSA's) strategic initiatives, such as military personnel and people involved in or at risk of involvement in the criminal justice system. Many diverse data sources were used to produce the estimates, including sources that examine service use at the national level, such as the National Survey on Drug Use and Health (NSDUH) and the National Comorbidity Survey Replication, and sources that examine service use within specific specialty and nonspecialty treatment settings, such as the National Nursing Home Survey or the Nationwide Emergency Department Sample of the Healthcare Cost and Utilization Project.

This section also reports on the capacity of the mental health treatment system; that is, the number of institutions and professionals in both specialty and nonspecialty treatment settings. Service capacity is important to address in light of the recently passed health reform and mental health parity laws. Once fully implemented, these laws are likely to remove some barriers to behavioral health care, in which case it will be important that treatment capacity is adequate to meet the additional demand. For example, this volume includes estimates of specialty mental health treatment capacity from the National Survey of Mental Health Treatment Facilities.

### 3.1.2 Adult Mental Health Services

(Exhibits 6 through 9 and Tables 23 through 55)

#### Mental Health Services

People receive mental health treatment in a variety of ways, including specialty outpatient and inpatient care settings; general medical providers; nonspecialty settings, such as schools, nursing homes, or correctional facilities; and through prescription medication. Nationwide rates of mental health service utilization among adults by treatment setting are provided by self-reported mental health need (Tables 23, 24, and 26) and by individual characteristics (Tables 25, 27, and 28). Approximately one in eight adults in the United States received some type of specialty mental health treatment in the past year. More specifically, in 2009, 13.3 percent of all U.S. adults (or over 30 million) used outpatient, inpatient, or prescription medication treatment for a mental health problem in the past year (Exhibit 7 and Table 25). Over 11 percent—about 85 percent of the 13 percent—used prescription medication (Table 25). Among adults with any mental illness (AMI), 21.2 percent received outpatient mental health treatment, 3.1 percent received inpatient treatment, and 32.4 percent received a prescription medication for mental health (Table 24). For adults with serious mental illness (SMI), the corresponding proportions were 38.0 percent (outpatient), 6.8 percent (inpatient), and 54.0 percent (medication). However, a high proportion of adults with AMI (62.1 percent) or SMI (39.8 percent) did not receive any mental health services (Exhibit 6 and Table 24). Since 2002, adults' use of specialty outpatient mental health treatment has declined slightly, while inpatient treatment use has remained fairly stable (Exhibit 8 and Table 26).

Prescription medication has become an increasingly important component of behavioral health treatment in recent years, accounting for a growing share of spending (Mark, Levit, Vandivort-Warren, Buck, & Coffey, 2011). This is illustrated by information on trends in mental health/substance abuse (MH/SA) prescription medication fills among adults from 1996 to 2008 (Exhibit 9 and Tables 30 and 31). The data indicate that the number of prescription fills for these medications more than doubled between 1996 and 2008, which corresponds to 7 percent annual growth. However, this growth was general to all pharmaceuticals and not unique to MH/SA medications. Within the MH/SA category, three of the four medication classes reported (antidepressant, antipsychotic, and antimanic) increased at faster rates, with only antianxiety medications experiencing slower than average growth in prescribing (Exhibit 9 and Tables 30 and 31).

#### Nonspecialty Mental Health Services

Nonspecialty mental health services are a key part of mental health treatment for adults in the United States. This volume provides information on services used by individuals in several important nonspecialty sectors, including emergency departments (Tables 32, 33, 34, 35, 36, and 37); physicians' offices (Tables 38, 39, and 40); nursing homes, home health care agencies, and hospice facilities (Table 41); and clubhouses (Tables 42, 43, and 44). Clubhouses follow a model of service provision that focuses on the nonclinical aspects of helping people with severe and persistent mental illness. Clubhouses often provide, for example, employment services.

Emergency departments are intended to serve people with acute need, such as those with an acute mental health episode. However, this setting also serves many people who do not have insurance because the uninsured cannot be refused care at a hospital. Moreover, because a disproportionate share of people with mental illness are uninsured (Hazlett, McCarthy, Londner, & Onyike, 2004), emergency departments serve a disproportionate number of people with mental illness. In 2008, mental health was the primary diagnosis for 4.5 percent of emergency department visits by youth aged 10 to 17 (see Table 34) and 5 percent of visits by adults aged 18 to 64, but for only 2 percent of visits by adults aged 65 or older (see Table 33). Also, among those with a primary mental health diagnosis, diagnosis categories differed by age group. For youth with a primary mental health diagnosis, the most common categories were mood disorders (34.6 percent); anxiety disorders (14.9 percent); and attention deficit, conduct, and disruptive behavior disorders (12.7 percent). For adults, attention deficit, conduct, and disruptive behavior disorders accounted for less than 1 percent of visits, but other categories were much more important, such as alcohol and substance-related disorders, particularly for those aged 18 to 64 (see Table 33).

Physicians' offices also are commonly used for mental health problems. Indeed, general practice physicians write the majority of prescriptions for psychotropic medication (Mark, Levit, & Buck, 2009). Given the prominence of medication in treating mental health conditions (see Table 25), data are needed on treating mental health in physicians' offices. In 2008, more than 6 percent of all office visits involved any mental diagnosis, and 3.9 percent involved a primary diagnosis (Table 38). Nonspecialty care physicians also play an important role, with specialties other than psychiatry accounting for 44 percent of visits with a primary mental diagnosis (Table 39) and 63.3 percent of visits with any mental diagnosis (Table 40).

#### Mental Health Service Capacity

In presenting data on the capacity of mental health treatment specialty and nonspecialty systems, the demographic characteristics of the behavioral health workforce are important to consider because they may affect some patients' experience of treatment. Estimates portray characteristics of clinically trained mental health personnel in terms of their age, sex, and Hispanic origin and race, by provider type (Table 45). Prior research has identified a demographic mismatch between patients and providers that is larger for behavioral health care than for general medical care (Miranda, McGuire, Williams, & Wang, 2008). This section also illustrates time trends from 1986 to 2004 in the number of mental health organizations with 24-hour hospital/residential treatment settings and the corresponding number of beds relative to the population (Tables 46 and 47).

Evidence on the capacity of nonspecialty service settings includes data on the service capacity of jails, prisons, and correctional facilities (Tables 48 and 49); community health centers (CHCs) (Tables 50, 51, 52, and 53); and clubhouses (Table 54). These service locations often play an important role in mental health treatment. For instance, CHCs are an important part of the safety net for mental health care, and their role is likely to be enhanced under health reform (Lo Sasso & Byck, 2010). Estimates show the growth over time in the proportion of CHCs providing behavioral health services (Table 51) and in the number of specialty mental health and substance abuse encounters at CHCs (Table 53) for the period 1998 through 2007. Many psychiatric patients continue to be seen in general hospital beds (“scatter beds”) that are not part of psychiatric units. These discharges are compared with psychiatric unit discharges in terms of various patient, facility, and treatment characteristics. Comparisons are also made between discharges from scatter beds in hospitals with and without psychiatric units (Table 55).

### 3.1.3 Child Mental Health Services

(Exhibits 10 though 13 and Tables 56 through 66)

Because youth populations differ in important ways from adults, their service patterns are presented separately (Tables 56 to 66). Children and youth may receive mental health treatment across a variety of settings, including education and juvenile justice settings. In 2009, youth were most likely to have received mental health services in either specialty mental health outpatient or education settings. Specifically, 12.0 percent of youth aged 12 to 17 received specialty mental health treatment, with the most common source being outpatient care from a private therapist, psychologist, psychiatrist, social worker, or counselor (9.3 percent) (Exhibit 12 and Table 56). Also, 12.1 percent received mental health treatment from the education system, and 0.4 percent received treatment from the juvenile justice system (Exhibit 12 and Table 56).

#### Specialty Mental Health Services

More than half of children aged 8 to 15 with a mental disorder received some form of mental health treatment in the past year (Exhibit 10 and Table 57). Table 57 presents the proportion of children aged 8 to 15 with various mental disorders who saw someone at a hospital, clinic, or office because of a mental health problem. Children with anxiety disorders were less likely to receive treatment than children with mood or disruptive behavior disorders. Because attention deficit hyperactivity disorder (ADHD) is much more prevalent among youth, this section presents data on the use of prescription medicine for ADHD among youth aged 2 to 17. In 2007, 4.2 percent of U.S. children were taking prescription medication for ADHD (Table 58).

Patterns of mental health services for children with emotional disturbance have changed substantially over time, in particular the use of residential treatment centers (Table 61) and MH/SA medications (Tables 62 and 63). For instance, time trends from 1996 to 2008 in MH/SA prescription medication fills among youth aged 17 or younger are reported by selected medication classes (Exhibit 13 and Tables 62 and 63). MH/SA prescription medication fills for children have increased notably since 1996. The rise is driven largely by an increase in the use of stimulant medication, which is likely prescribed for ADHD.

#### Mental Health Service Capacity for Children

Information on mental health service capacity for children is presented for two specific service systems: residential treatment centers (Tables 64 and 65) and schools (Table 66). Information is provided on the number of residential treatment centers for children with emotional disturbance and the number of inpatient beds in State and county psychiatric hospitals among children aged 17 or younger (Tables 64 and 65). Data are also shown on the percentage of schools that provided various mental health, social, or prevention services in 2006 and the methods they used to deliver those services (Table 66). The table indicates, for example, that more than 95 percent of schools provided crisis intervention for personal problems. Other common services provided by schools include identification of abuse, identification of family problems, and counseling for emotional or behavioral disorders (Table 66).

### 3.1.4 Special Populations

(Tables 67 through 69)

SAMHSA's strategic initiatives highlight the importance of providing support and treatment to America's service men and women, together with their families and communities, and of meeting the behavioral health needs of incarcerated adults and children (SAMHSA, 2011). The final set of tables on providers and settings of care contains estimates on service use in military populations (Tables 67 and 68) and youth in the juvenile justice system (Table 69). Among active duty military in 2008, 8.5 percent reported receiving prescribed medication for depression, anxiety, or sleeping problems; nearly 20 percent received mental health counseling (Table 67). In 2003, 52.7 percent of youth in the juvenile justice system received some form of counseling (Table 69).

## 3.2 Exhibits

Exhibits 6–13

### Receipt of Mental Health Treatment by Adults with Any Mental Illness and Serious Mental Illness

A significant proportion of adults with serious mental illness do not report receiving treatment.

People with serious mental illness (SMI) are of particular concern to providers and policy makers. SMI impairs functioning in everyday life and can cause great distress. Treatment for people with SMI is particularly important in aiding recovery. The National Survey on Drug Use and Health (NSDUH) includes questions that assess types of mental health treatment received by U.S. adults. Exhibit 6 describes the types of mental health treatment received by people with any mental illness (AMI), as well as treatment received specifically by people with SMI. Individuals may receive more than one type of treatment. The exhibit shows the following:

■ In 2009, individuals with SMI were more likely to receive mental health treatment than individuals with AMI, but both groups were often unlikely to receive any treatment. Among those with AMI in the past year, 62.1 percent (or an estimated 27.9 million people) did not receive treatment. Among those with SMI, 39.8 percent (or an estimated 4.3 million people) did not receive treatment.
■ The most common form of mental health treatment for individuals with either AMI or SMI was prescription medication.

Exhibit 6 Percentage of persons aged 18 or older who received mental health treatment in the past year, by mental illness status, United States, 2009

NOTES: Any mental illness (AMI) among adults is defined as persons aged 18 or older who currently or at any time in the past year had a diagnosable mental, behavioral, or emotional disorder, regardless of the level of impairment in carrying out major life activities. AMI includes persons with mental illness having serious, moderate, or mild functional impairment. Serious mental illness (SMI) is a subset of the AMI group. SMI among adults is defined as persons aged 18 or older who currently or at any time in the past year had a diagnosable mental, behavioral, or emotional disorder and resulting in substantial impairment in carrying out major life activities. See Table 24 for more details on the constructs in this exhibit.

Respondents with unknown treatment/counseling information were excluded. Respondents could indicate multiple service sources; thus, these response categories are not mutually exclusive.

SOURCE: National Survey on Drug Use and Health, 2009, Substance Abuse and Mental Health Services Administration, Office of Applied Studies.

Exhibit 6 is a bar chart showing the percentages of persons aged 18 or older who received mental health treatment in the past year by mental illness status in the United States in 2009. 21.2% of persons aged 18 or older with any mental illness received outpatient mental health treatment. 3.1% of persons aged 18 or older with any mental illness received inpatient mental health treatment. 32.4% of persons aged 18 or older with any mental illness received prescription medication for a mental health problem. 62.1% of persons aged 18 or older with any mental illness did not receive mental health outpatient, inpatient, or prescription medication treatment. 38.0% of persons aged 18 or older with serious mental illness received outpatient mental health treatment. 6.8% of persons aged 18 or older with serious mental illness received inpatient mental health treatment. 54.0% of persons aged 18 or older with serious mental illness received prescription medication for a mental health problem. 39.8% of persons aged 18 or older with serious mental illness did not receive mental health outpatient, inpatient, or prescription medication treatment.

### Mental Health Service Use by Key Characteristics

Approximately one in eight adults in the United States received some type of mental health specialty outpatient, inpatient, or prescription medication treatment in the past year.

The receipt of mental health treatment varies by key characteristics of the recipients. Exhibit 7 uses the 2009 National Survey on Drug Use and Health (NSDUH) to show how mental health treatment use for adults varied by important demographic and socioeconomic factors. This exhibit shows adults' report of mental health treatment receipt and provides population estimates not limited to individuals with mental health problems. The exhibit shows the following:

■ A higher proportion of women than men received mental health treatment in the past year (17.1 versus 9.2 percent, respectively).
■ Among the three Hispanic origin and race groups examined, non-Hispanic whites had the highest proportion of treatment receipt (16.0 percent).
■ Adults who were covered by Medicaid or the Children's Health Insurance Program (CHIP) had particularly high rates of mental health treatment receipt (23.6 percent) compared with adults covered by other types of insurance (14.0 percent for some other form of coverage).

Exhibit 7 Percentage of persons aged 18 or older who received mental health treatment or counseling in the past year, by selected characteristics, United States, 2009

NOTES: Mental health treatment or counseling is defined as having received outpatient care or inpatient care or having used prescription medication for problems with emotions, nerves, or mental health. Respondents with unknown treatment/counseling information were excluded.

Poverty status is based on respondent age, family income, family size, and composition using the U.S. Census Bureau's poverty thresholds. “Poor” persons are defined as living in households where the family income is less than 100 percent of the U.S. Census poverty threshold. “Near poor” persons have incomes of 100 percent to less than 200 percent of the poverty threshold. “Not poor” persons have incomes that are 200 percent of the poverty threshold or greater.

CHIP is the Children's Health Insurance Program. Respondents could indicate multiple types of health insurance; thus, these response categories are not mutually exclusive. See Table 25 for more details on the constructs in this exhibit.

SOURCE: National Survey on Drug Use and Health, 2009, Substance Abuse and Mental Health Services Administration, Office of Applied Studies.

Exhibit 7 is a bar chart showing the percentages of persons aged 18 or older who received mental health treatment or counseling in the past year by selected characteristics in the United States in 2009. The total percentage of persons aged 18 or older who received mental health treatment or counseling in the past year is 13.3%. Percentage of persons 18 to 25 years old is 11.1%. Percentage of persons 26 to 49 years old is 14.6%. Percentage of persons 50 years or older is 12.8%. Percentage of males is 9.2%. Percentage of females is 17.1%. Percentage of whites is 16.0%. Percentage of blacks or African Americans is 7.7%. Percentage of Hispanics or Latinos is 7.3%. Percentage of poor is 15.8%. Percentage of near poor is 12.8%. Percentage of not poor is 13.0%. Percentage of people with private health insurance coverage is 12.7%. Percentage of people with Medicaid/CHIP insurance coverage is 23.6%. Percentage of people with other health insurance coverage is 14.0%. Percentage of people with no health insurance coverage is 9.1%.

### Adults Using Outpatient and Inpatient Mental Health Treatment

Since 2002, adult use of outpatient mental health treatment has declined slightly, while inpatient treatment use has remained stable.

Mental health treatment may include outpatient and inpatient care. It is important to understand the degree to which both types of treatment have changed over time. The National Survey on Drug Use and Health (NSDUH) includes questions that assess the types of mental health treatment received by U.S. adults. Exhibit 8 describes the proportion of adults between 2002 and 2009 using outpatient or inpatient mental health treatment. This exhibit does not include estimates of adults' self-reported use of prescription medication for a mental health problem. The exhibit shows the following:

■ Over the 8-year period studied, the proportion of adults using outpatient treatment declined from 7.4 percent in 2002 to 6.3 percent in 2009.
■ Use of inpatient treatment remained stable at 1 percent or less of the U.S. adult population.

Exhibit 8 Percentage of persons aged 18 or older who received mental health treatment or counseling in the past year, United States, 2002–2009

NOTES: Respondents could indicate multiple service sources; thus, these response categories are not mutually exclusive. Outpatient treatment includes any mental health treatment or counseling received at an outpatient mental health clinic or center; the office of a private therapist, psychologist, psychiatrist, social worker, or counselor that was not part of a clinic; a doctor's office that was not part of a clinic; an outpatient medical clinic; a partial day hospital or day treatment program; or some other place. Inpatient treatment includes a stay of overnight or longer in a hospital or other facility for mental health problems. See Tables 25 and 26 for more details on the constructs in this exhibit.

SOURCE: National Survey on Drug Use and Health, 2002–2009, Substance Abuse and Mental Health Services Administration, Office of Applied Studies.

Exhibit 8 is a line graph showing the percentages of persons aged 18 or older who received mental health treatment in the past year in the United States from 2002 to 2009. Percentages of persons aged 18 or older who received outpatient mental health treatment in the past year are the following: 2002 is 7.4%, 2003 is 7.1%, 2004 is 7.1%, 2005 is 6.8%, 2006 is 6.7%, 2007 is 6.9%, 2008 is 6.8%, 2009 is 6.3%. Percentages of persons aged 18 or older who received inpatient mental health treatment in the past year are the following: 2002 is 0.7%, 2003 is 0.8%, 2004 is 0.9%, 2005 is 1.0%, 2006 is 0.7%, 2007 is 1.0%, 2008 is 0.9%, 2009 is 0.8%.

### Mental Health/Substance Abuse Medication Fills among Adults

The rise from 1996 to 2008 in mental health/substance abuse medication fills for adults was driven largely by antidepressant medication.

In the past decade, medication has become an increasingly prominent part of treatment for behavioral health problems. One way to measure the use of medication is to examine data from pharmacies on the number of prescriptions being purchased or filled. The Medical Expenditure Panel Survey (MEPS) includes a component that gathers data about prescription medication fills directly from pharmacies across the United States. This data collection method makes MEPS a particularly reliable source of information for assessing trends in psychotropic medication. Exhibit 9 shows, for four major classes of psychotropic medication, the extent of the increase in prescription fills from 1996 to 2008. The measure includes first-time purchases and refills. The exhibit shows the following:

■ Throughout the period studied, antidepressant medication was the most common class of medication filled, and antianxiety medication was the second most common.
■ The increase in medication fills over the period was driven largely by antidepressant medication. This class of medication had the largest increase in medication fills over the period, from 55.9 million fills in 1996 to 154.7 million fills in 2008.
■ Fills for other classes of medications also increased over the period studied. For example, antianxiety medications—the second most common psychotropic medication—rose from 32.6 million in 1996 to 54.3 million in 2008. In 1996, the number of antianxiety medication fills was about 60 percent of the number of antidepressant fills; by 2008, that proportion fell to about 30 percent.

Exhibit 9 Mental health/substance abuse medication fills among persons aged 18 or older, United States, 1996–2008

NOTES: For legibility, data labels for antipsychotic and antimanic medications are suppressed.

Antianxiety medications include sedative and hypnotic medications.

See Appendix C for complete list of medications. Categorization of medications follows that of the National Institute of Mental Health (http://www.nimh.nih.gov/health/publications/mental-health-medications/alphabetical-list-of-medications.shtml). See Tables 30 and 31 for more details on the constructs in this exhibit.

SOURCE: Medical Expenditure Panel Survey, 1998–2008, Center for Financing, Access, and Cost Trends, Agency for Healthcare Research and Quality.

Zuvekas, S. H. (2005). Prescription drugs and the changing patterns of treatment for mental disorders, 1996–2001. Health Affairs, 24(1), 195–205.

Exhibit 9 is a line graph showing the numbers, in millions, of mental health/substance abuse medication fills among persons aged 18 or older from 1996 to 2008. The numbers, in millions, of persons age 18 or older who filled mental health/substance abuse medication, including all mental health medications are as follows: 1996 is 105.4, 1997 is 116.9, 1998 is 127.2, 1999 is 131.3, 2000 is 150.3, 2001 is 175.0, 2002 is 200.4, 2003 is 206.1, 2004 is 221.5, 2005 is 239.9, 2006 is 242.6, 2007 is 248.8, and 2008 is 263.0. The number, in millions, of persons age 18 or older who filled antipsychotic medications are as follows: 1996 is 9.3, 1997 is 12.8, 1998 is 11.7, 1999 is 10.9, 2000 is 14.4, 2001 is 15.1, 2002 is 16.2, 2003 is 15.0, 2004 is 15.5, 2005 is 18.5, 2006 is 20.6, 2007 is 22.8, and 2008 is 23.0. The number, in millions, of persons age 18 or older who filled antianxiety medications, are as follows: 1996 is 32.6, 1997 is 31.8, 1998 is 30.6, 1999 is 29.5, 2000 is 33.0, 2001 is 39.4, 2002 is 44.4, 2003 is 40.8, 2004 is 41.5, 2005 is 48.7, 2006 is 46.1, 2007 is 48.2, and 2008 is 54.3. The numbers, in millions, of persons age 18 or older who filled antidepressant medication, are as follows: 1996 is 55.9, 1997 is 63.0, 1998 is 74.4, 1999 is 74.6, 2000 is 86.1, 2001 is 102.3, 2002 is 120.1, 2003 is 127.6, 2004 is 141.5, 2005 is 149.7, 2006 is 150.7, 2007 is 148.0, and 2008 is 154.7. The numbers, in millions, of persons age 18 or older who filled antimanic and anticonvulsant medications are as follows: 1996 is 6.2, 1997 is 7.5, 1998 is 7.9, 1999 is 6.2, 2000 is 11.5, 2001 is 12.9, 2002 is 13.2, 2003 is 14.0, 2004 is 14.3, 2005 is 13.3, 2006 is 13.7, 2007 is 17.1, and 2008 is 16.9.

### Mental Health Service Receipt by Children and Youth Aged 8 to 15 with Selected Mental Disorders

More than half of children aged 8 to 15 with a selected mental disorder received any mental health treatment in the past year.

Children and youth with mental disorders are vulnerable to experiencing problems at home, with peers, and in school. Having friends, academic achievement, and strong family relationships are critical to positive child development and the successful transition to early adulthood. This makes early mental health treatment engagement for children with emotional and behavioral disorders particularly important, especially among children also experiencing severe functional impairment. Findings from the National Health and Nutrition Examination Survey (NHANES) as reported in Merikangas et al. (2010) show the percentage of children aged 8 to 15 with particular past year emotional or behavioral disorders who received mental health treatment. This NHANES-based study included 3,042 participants aged 8 to 15 who had participated in one of the NHANES surveys between 2001 and 2004. This study showed the following:

■ About half of children aged 8 to 15 with at least one of the mental disorders assessed received mental health services in the past year.
■ Children with mental disorders with severe impairment were no more likely to have received a mental health service in the past year than children with any emotional or behavioral disorder (with or without severe impairment).
■ Children with anxiety disorders were the least likely to have received treatment. Only one in three children with anxiety disorders, with or without severe impairment (32.2 percent and 33.9 percent, respectively), reported receiving treatment in the past year.

Exhibit 10 Percentage of persons aged 8 to 15 with selected mental disorders who received mental health treatment in the past year, by level of impairment, United States, 2001–2004

NOTES: Mental disorders were assessed using a structured diagnostic interview that contained modules. Disorder with severe impairment indicates two intermediate ratings or one severe rating on the six impairment questions within a diagnostic module. See Table 57 for more details on the constructs in this exhibit.

ADHD = attention deficit hyperactivity disorder.

SOURCE: Merikangas, K. R., He, J.-P., Brody, D., Fisher, P. W., Bourdon, K., & Koretz, D. S. (2010). Prevalence and treatment of mental disorders among US children in the 2001–2004 NHANES. Pediatrics, 125(1), 75–81.

Exhibit 10 is a bar graph showing the percentage of persons aged 8 to 15 with selected mental disorders who received mental health treatment in the past year, by level of impairment in the United States from 2001 to 2004. 50.6% of all cases with any mental health disorder received mental health treatment; 52.8% of cases with severe impairment received mental health treatment; 47.7% of all cases with ADHD received mental health treatment; 48.5% of ADHD cases with severe impairment received mental health treatment; 46.4% of all cases with conduct disorder received mental health treatment; 44.2% of conduct disorder cases with severe impairment received mental health treatment; 32.2% of all cases with anxiety disorder received mental health treatment; 33.9% of anxiety disorder cases with severe impairment received mental health treatment; 43.8% of all cases with mood disorders received mental health treatment; 50.7% of mood disorder cases with severe impairment received mental health treatment.

### Youth Receiving Specialty Mental Health Treatment in the Past Year by Key Characteristics

Female youth were more likely to have received specialty mental health treatment than male youth.

Use of mental health treatment among youth varies according to some key characteristics, particularly sex. Use of mental health treatment among youth, however, does not vary significantly by other characteristics, such as age and poverty. The National Survey on Drug Use and Health (NSDUH) includes questions that ask youth aged 12 to 17 to self-report on their receipt of specific types of specialty mental health treatment. Based on NSDUH data from 2009, mental health treatment use among youth aged 12 to 17 varied by important demographic and socioeconomic factors (Exhibit 11). The exhibit shows the following:

■ Female youth were more likely to have received specialty mental health treatment in the past year than male youth (14.0 percent versus 10.1 percent). This difference was driven largely by the higher likelihood for female youth to receive specialty outpatient services. Use of specialty inpatient mental health treatment did not differ significantly by sex.
■ Use of specialty mental health treatment by youth did not differ significantly by age, Hispanic origin and race, or poverty status.

Exhibit 11 Percentage of persons aged 12 to 17 who received any specialty mental health treatment in the past year, by selected characteristics, United States, 2009

NOTES: Specialty mental health treatment includes outpatient mental health treatment or inpatient or residential care.

Poverty status is based on respondent age, family income, family size, and composition using the U.S. Census Bureau's poverty thresholds. “Poor” persons are defined as living in households where the family income is less than 100 percent of the U.S. Census poverty threshold. “Near poor” persons have incomes of 100 percent to less than 200 percent of the poverty threshold. “Not poor” persons have incomes that are 200 percent of the poverty threshold or greater.

Respondents with unknown receipt of mental health service information were excluded. Respondents could indicate multiple service sources; thus, the response categories are not mutually exclusive. See Table 59 for more details on the constructs in this exhibit.

SOURCE: National Survey on Drug Use and Health, 2009, Substance Abuse and Mental Health Services Administration, Office of Applied Studies.

Exhibit 11 is a bar chart showing the percentage of persons aged 12 to 17 who received any specialty mental health treatment in the past year by selected characteristics in the United States in 2009. The total number of persons is 12.0%; 11.6% aged 12 to 13; 12.3% aged 14 to 15; 12.1% aged 16 to 17; 10.1% of males; 14.0% of females; 12.8% of whites; 12.2% of Blacks or African Americans; 10.2% of Hispanics or Latinos; 12.3% of poor; 12.8% of near poor; 11.6% of not poor.

### Mental Health Service Use by Youth Aged 12 to 17 by Type of Treatment and Treatment Setting

Youth are most likely to have received mental health services in either specialty mental health outpatient or education settings.

Children and youth with emotional or behavioral health disorders receive mental health treatment in a variety of settings, including specialty mental health and nonspecialty settings. Nonspecialty settings, such as schools or primary care, are particularly important service settings to both identify emotional and behavioral health problems in childhood and provide services to children and youth with emotional or behavioral health disorders. The National Survey on Drug Use and Health (NSDUH) includes questions that assess the types of specialty and nonspecialty mental health treatment received by U.S. youth aged 12 to 17. Youth are asked to self-report on each type of treatment received in the past year and can indicate more than one type of treatment. Exhibit 12 presents data on mental health treatment for youth aged 12 to 17:

■ In 2009, 12.0 percent of U.S. youth aged 12 to 17 reported using specialty mental health services in the past year, including services in inpatient (including residential treatment and treatment through therapeutic foster care) and outpatient mental health treatment locations.
■ Approximately the same percentage of youth (12.1 percent) reported receiving some mental health–related service in an education setting. This included talking with a school social worker, psychologist, or counselor; receiving special education services; or being placed in a special school or program for students with emotional or behavioral problems.
■ Of the 2.9 million youth who received any specialty mental health services in the past year, the majority (10.8 percent or 2.6 million) received outpatient treatment services and 2.3 percent (0.6 million) received inpatient services with some of these youth receiving both outpatient and inpatient treatment services.

Exhibit 12 Percentage of persons aged 12 to 17 who received mental health treatment in the past year, by type of treatment and treatment setting, United States, 2009

NOTES: Receipt of mental health services for persons aged 12 to 17 is defined as having received treatment/counseling for emotional or behavioral problems not caused by drug or alcohol use. Respondents with unknown receipt of mental health service information were excluded. Respondents could indicate multiple service sources; thus, the response categories are not mutually exclusive. See Table 59 for more details on the constructs in this exhibit.

SOURCE: National Survey on Drug Use and Health, 2009, Substance Abuse and Mental Health Services Administration, Office of Applied Studies.

Exhibit 12 is a bar chart showing the percentage of persons aged 12 to 17 who received mental health treatment in the past year by type of treatment and treatment setting in the United States in 2009. A total of 12.0% received specialty mental health services; 10.8% received outpatient specialty mental health services; 2.3% received inpatient or residential specialty mental health services. 12.1% received education nonspecialty mental health services; 2.5% received medical nonspecialty mental health services; 0.4% received juvenile justice nonspecialty mental health services.

### Mental Health/Substance Abuse Medication Fills among Children

The increase from 1996 to 2008 in psychotropic medication fills for children was driven largely by an increase in the use of stimulant medication.

Psychotropic medication is an important part of mental health treatment for children, and the role of medication in treatment has become more prominent in recent years. Data from pharmacy records on the number of prescriptions being purchased or filled provide one useful metric to monitor prescription medication use. The Medical Expenditure Panel Survey (MEPS) includes a component that gathers data about prescription medication fills directly from pharmacies across the United States. This data collection method makes MEPS a particularly reliable source of information for assessing trends in psychotropic medication. Exhibit 13 illustrates the increase in psychotropic prescription medication fills for three major classes of psychotropic medication from 1996 to 2008: antidepressant, antipsychotic, and stimulant. These prescription fills were specifically for the treatment of a childhood emotional or behavioral health problem. The measure includes first-time purchases and refills. The exhibit shows the following:

■ The number of psychotropic medication fills for children nearly doubled between 1996 and 2008.
■ Consistently over time, stimulant medication was the most common class of examined psychotropic medication filled. Antidepressant medication was the second most common.
■ The increase in psychotropic medication fills from 1996 to 2008 was driven largely by stimulant medications.
■ Over time, the number of antidepressant medication fills has been about one quarter of the number of stimulant fills.
■ Antipsychotic medication use appears to have become more prominent over time. Before 2001, data on these fills did not include a sufficient number to be reported reliably for children. In 2001, the first year for which reliable estimates could be obtained, the number of fills was 1.4 million. By 2005, that number had risen to 4 million, and the number remained about or just below that level until 2008. Evidence elsewhere in this volume (see Exhibit 20) suggests that changes in fills for antipsychotic medication are driven by the number of people being prescribed medication, rather than the number of fills being prescribed per person.

Exhibit 13 Trends in mental health/substance abuse medication fills for persons aged 17 or younger, by medication class, United States, 1996–2008

NOTES: Estimates for antipsychotic medication before 2001 are considered unreliable.

Antianxiety medications include sedative and hypnotic medications.

See Appendix C for complete list of medications. Categorization of medications follows that of the National Institute of Mental Health (http://www.nimh.nih.gov/health/publications/mental-health-medications/alphabetical-list-of-medications.shtml). See Tables 62 and 63 for more details on the constructs in this exhibit.

SOURCES: Medical Expenditure Panel Survey, 1996–2008, Center for Financing, Access, and Cost Trends, Agency for Healthcare Research and Quality.

Zuvekas, S. H. (2005). Prescription drugs and the changing patterns of treatment for mental disorders, 1996–2001. Health Affairs, 24(1), 195–205.

Exhibit 13 is a line graph showing trends in mental health/substance abuse medication fills for persons aged 17 or younger, by medication class from 1996 to 2008. The number, in millions, of prescription fills for persons aged 17 or younger for all classes of medication: 1996 is 15.6, 1997 is 17.5, 1998 is 18.7, 1999 is 18.6, 2000 is 20.2, 2001 is 22.4, 2002 is 24.2, 2003 is 29.0, 2004 is 29.5, 2005 is 31.4, 2006 is 32.2, 2007 is 27.6, and 2008 is 30.2. The number, in millions, of prescription fills for persons aged 17 or younger for stimulant medications: 1996 is 11.1, 1997 is 11.9, 1998 is 13.2, 1999 is 13.8, 2000 is 12.2, 2001 is 14.2, 2002 is 13.4, 2003 is 17.1, 2004 is 18.5, 2005 is 18.7, 2006 is 19.9, 2007 is 18.8, and 2008 is 20.6. The number, in millions, of prescription fills for persons aged 17 or younger for antidepressant medication: 1996 is 2.6, 1997 is 3.9, 1998 is 3.5, 1999 is 3.5, 2000 is 5.5, 2001 is 5.2, 2002 is 6.5, 2003 is 7.3, 2004 is 6.1, 2005 is 6.5, 2006 is 5.8, 2007 is 4.2, and 2008 is 4.9. The number, in millions, of prescription fills for persons aged 17 or younger for antipsychotic medication: 2001 is 1.4, 2002 is 1.5, 2003 is 2.0, 2004 is 2.6, 2005 is 4.0, 2006 is 3.7, 2007 is 2.5, and 2008 is 3.8.

## 3.3 References

Hazlett SB, McCarthy ML, Londner MS, Onyike CU. February. Epidemiology of adult psychiatric visits to US emergency departments. Academic Emergency Medicine. 2004;11(2):193-195. [pmid: 14759965].
Lo Sasso AT, Byck GR. Funding growth drives community health center services. Health Affairs. 2010;29(2):289-296. [pmid: 20348076].
Mark TL, Levit KR, Vandivort-Warren R, Buck JA, Coffey RM. Changes in US spending on mental health and substance abuse treatment, 1986–2005, and implications for policy. Health Affairs. 2011;30(2):284-292. [pmid: 21289350].
Mark TL, Levit KR, Buck JA. Datapoints: Psychotropic drug prescriptions by medical specialty. Psychiatric Services. 2009;60(9):1167. [pmid: 19723729].
Merikangas KR, He JP, Brody D, Fisher PW, Bourdon K, Koretz DS. Prevalence and treatment of mental disorders among US children in the 2001–2004 NHANES. Pediatrics. 2010;125(1):75-81. [pmid: 20008426].
Miranda J, McGuire TG, Williams DR, Wang P. Mental health in the context of health disparities. American Journal of Psychiatry. 2008;165(9):1102-1108. [pmid: 18765491].
Substance Abuse and Mental Health Services Administration (SAMHSA). 2011. Leading change: A plan for SAMHSA's roles and actions 2011–2014. (DHHS Publication No. SMA 11-4629). Rockville, MD. SAMHSA. Retrieved from http://store.samhsa.gov/product/SMA11-4629.
Zuvekas SH. Prescription drugs and the changing patterns of treatment for mental disorders, 1996–2001. Health Affairs. 2005;24(1):195-205. [pmid: 15647230].