# MENTAL HEALTH OF THE POPULATION

## 2.1 Narrative

### 2.1.1 Overview

Mental disorders are common, often serious, and treatable disorders that have a major impact on the U.S. population. An essential building block in the effort to prevent, treat, and assist in recovery from mental disorders is an understanding of the prevalence of mental disorders. Prevalence estimates contribute to developing an accurate picture of the level and type of mental health care needs for the overall U.S. population, as well as the risk of mental disorders within specific subpopulations of interest. National prevalence estimates can indicate the prevalence of any mental disorder or specific types of mental disorders, their severity or impairment level, and changes in the prevalence of the disorder over time.

This section presents mental disorder prevalence information for adults and children, rates of co-occurring health and substance abuse problems with mental health problems, suicide prevalence rates, and indicators of mental health status within selected special populations, including military personnel and children in the child welfare system. The tables present estimates from a variety of data sources, including the two national surveys that collect annual indicators of mental health status in the U.S. population: the National Survey on Drug Use and Health (NSDUH) and the National Health Interview Survey (NHIS). This section addresses several of the strategic initiatives of the Substance Abuse and Mental Health Services Administration (SAMHSA), which support its mission to reduce the impact of substance abuse and mental illness on America's communities (SAMHSA, 2011). For example, a number of tables specifically pertain to SAMHSA's strategic initiatives on Trauma and Justice and on Military Families.

### 2.1.2 U.S. Population: Adults

(Exhibits 1 through 3 and Tables 1 through 7)

Estimates relevant to the U.S. adult population include the prevalence of mental disorders, serious mental illness (SMI), and serious psychological distress (SPD). The first estimates presented are of any mental illness (AMI) and SMI, which refers to diagnosable mental disorders that result in serious functional impairment (Tables 1 and 2). Other estimates describe the prevalence of major depressive episode (MDE) (Tables 3 and 4) and past 30-day SPD (Tables 5 through 7). SPD does not represent a diagnosis; rather, it reflects the presence of mental health symptoms that may negatively affect a person's ability to participate in family, community, and work life. This construct is measured by a symptom scale designed to assess recent psychological distress (within the past 30 days). Whereas the concept of and term SMI is widely used by providers and policy makers, SPD is not as well known.

In 2009, 19.9 percent of the U.S. adult population experienced AMI (excluding substance use disorders) in the past year (Table 1). Prevalence of AMI was higher for females (23.8 percent) than males (15.6 percent). AMI also was higher for persons with Medicaid or Children's Health Insurance Program (CHIP) coverage (33.4 percent) or who are uninsured (24.9 percent) than for persons with private insurance (17.3 percent) or other coverage (16.1 percent). Exhibit 1 and Table 1 also indicate that 4.8 percent of adults had SMI, which equates to approximately 11 million U.S. adults annually. Table 2 shows the prevalence of specific types of mental disorder, including anxiety, mood, impulse control, and substance use disorders.

Major depressive disorder (MDD) is a serious mental disorder that can result in impairment and societal costs, including work disability and lost productivity (Katon, 2009). MDE indicates the presence of a 2-week period in the past year when a person experienced depressed mood, which is one of the components of the diagnostic criteria for MDD. In 2009, 6.5 percent of U.S. adults experienced MDE in the past year (Table 3). Table 4 shows annual prevalence estimates of MDE from 2005 to 2009.

In 2009, 3.2 percent of U.S. adults experienced SPD in the past 30 days (Table 5). Exhibit 2 and Table 6 show annual prevalence estimates for SPD over time. The estimates demonstrate that national levels of recent psychological distress in adults have remained relatively stable for more than a decade. Table 7 displays rates of past 30-day SPD for persons with selected physical health disorders (e.g., asthma, diabetes, cancer).

### 2.1.3 U.S. Population: Children

(Exhibit 4 and Tables 8 through 12)

Children experience emotional and behavioral problems that are specific to childhood (e.g., separation anxiety, enuresis). Furthermore, the prevalence of mental disorders seen in adulthood, such as major depression, is different in children. Prevalence data for children in the United States include estimates of emotional and behavioral difficulties (Table 8), mental disorders (Table 9), attention deficit hyperactivity disorder (ADHD) (Table 10), and MDE (Tables 11 and 12).

It is estimated that one out of eight U.S. children has had some form of an emotional or behavioral health disorder in the past year (Merikangas et al., 2010). Based on combined data from 2001 through 2004, prevalence of diagnosable mental disorders with severe impairment was 11.3 percent for children aged 8 to 15, and ADHD was the most common specific disorder (Exhibit 4 and Table 9). In 2009, ADHD was more than twice as prevalent among males as females (Table 10). Table 11 presents MDE prevalence rates for youth aged 12 to 17, broken out by demographic characteristics. In 2009, MDE was more prevalent among female youth (11.7 percent) than male youth (4.7 percent).

### 2.1.4 Substance Abuse

(Tables 13 and 14)

Persons with co-occurring mental and substance use disorders are an important subpopulation of interest. These individuals may experience treatment challenges and poorer outcomes (Najt, Fusar-Poli, & Brambilla, 2011) and may not receive integrated treatment that treats both disorders contemporaneously, as recommended (SAMHSA, 2007). Estimates are provided to illustrate the prevalence of substance dependence or abuse, including co-occurrence of substance dependence or abuse with AMI, SMI, and MDE for adults (Exhibit 3 and Table 13) and with MDE for youth aged 12 to 17 (Table 14).

In 2009, 19.7 percent of adults with AMI during the past year had a substance use disorder, with even higher prevalence among adults with SMI (25.7 percent) or MDE (22.4 percent). These are much higher rates of substance use disorders than experienced by persons without a mental disorder (6.5 percent) (Table 13). Past year co-occurring MDE and substance use disorder among youth also was common, occurring among 18.9 percent of youth with past year MDE (Table 14).

### 2.1.5 Suicide

(Exhibit 5 and Tables 15 and 16)

Suicide was the eleventh leading cause of death in the United States in 2007, accounting for more than 34,000 deaths (Xu, Kochanek, Murphy, & Tejada-Vera, 2010). Mental and substance use disorders are major risk factors for suicide (Goldsmith, Pellmar, Kleinman, & Bunney, 2002). In 2007, there were 11.3 suicides per 100,000 individuals in the U.S. population (Table 15). In that year, there were 0.5 suicides per 100,000 children aged 5 to 14 and 9.7 per 100,000 older adolescents and young adults aged 15 to 24 (Table 16). This subsection shows death rates for suicide by the most recent year (Table 15) as well as trends in death rates from 1985 to 2007 (Table 16). A limitation of these data is that they do not provide any information about suicide attempts.

Age-adjusted suicide rates are much lower for Hispanics (6.0 per 100,000 individuals in the U.S. population) than for non-Hispanics (12.0 per 100,000) (Table 15). The suicide rate for blacks is 5.0 per 100,000 in contrast with 12.5 per 100,000 for whites. As seen in Exhibit 5 and Table 16, suicide rates have decreased slightly from 12.5 per 100,000 individuals in the U.S. population in 1985 to 11.3 per 100,000 in 2007. The table also shows the much higher rates of suicide for men than for women (in 2007, 18.4 versus 4.7 per 100,000 population).

### 2.1.6 Special Populations

(Tables 17 through 22)

This subsection describes the prevalence of mental health disorders, behavioral and emotional problems, and symptoms within selected special populations. These special populations include persons aged 65 or older (Table 17), nursing home residents (Table 18), military personnel (Tables 19 and 20), inmates in State and Federal correctional facilities and local jails (Table 21), and children involved with the child welfare system (Table 22).

It is crucial to understand the extent of mental health needs of older adults, especially in an aging society. Projections indicate that almost one in five U.S. residents will be aged 65 or older in 2030 (Vincent & Velkoff, 2010). In 2009, 10.8 percent of persons aged 65 or older had past year AMI (Table 17). In 2004, nearly half (49.2 percent) of nursing home residents had a diagnosis of some type of mental illness (Table 18).

Active duty military personnel are another subpopulation of current interest. The length and nature of Operation Enduring Freedom (Afghanistan) and Operation Iraqi Freedom, and the multiple deployments that are often required, have put a spotlight on mental health issues, such as posttraumatic stress disorder (PTSD) and depression (Institute of Medicine, 2010). In 2008, 10.6 percent of active duty military personnel (Army, Navy, Marine Corps, Air Force, and Coast Guard) reported having possible PTSD symptoms in the past 30 days that suggested a need for further evaluation (Table 19). Table 20 presents similar types of data for National Guard and Reserve military personnel.

Large numbers of persons with mental illness reside within the Nation's prisons and jails, raising concerns about access to adequate treatment and whether programs to divert persons from incarceration into community treatment would better serve many of these offenders (Kuehn, 2007). A large proportion of inmates report having mental health problems: 44.8 percent of Federal prison inmates (in 2004), 56.2 percent of State prison inmates (in 2004), and 64.2 percent of local jail inmates (in 2002) (Table 21).

Many children involved in the child welfare system for maltreatment have emotional or behavioral health needs. In 2008, 22.6 percent of children reported for maltreatment showed symptoms consistent with a behavior problem as assessed by a standardized instrument of emotional and behavioral health (Table 22).

## 2.2 Exhibits

Exhibits 1–5

### Serious Mental Illness by Key Characteristics

In 2009, approximately 11 million U.S. adults had serious mental illness.

Serious mental illness (SMI) is defined as having a diagnosable mental, behavioral, or emotional disorder in the past year that results in serious functional impairment. These difficulties substantially interfere with a person's ability to carry out major life activities at home, at work, or in the community. Since 2008, the annual National Survey on Drug Use and Health (NSDUH) has included measures that permit the estimation of SMI in U.S. adults. NSDUH is a nationally representative survey of the civilian, noninstitutionalized population of the United States aged 12 or older and interviews approximately 67,500 persons each year.

Exhibit 1 shows rates of past year SMI by age, sex, Hispanic origin and race, poverty status, and health insurance status. The exhibit shows the following:

■ In 2009, 4.8 percent of U.S. adults aged 18 or older had SMI in the past year (representing an estimated 11.0 million U.S. adults).
■ The percentage of adults with past year SMI was highest among adults aged 18 to 25 (7.3 percent) and lowest among adults aged 50 or older (2.8 percent).
■ Past year SMI was more likely among women aged 18 or older (6.4 percent) than among men in that age group (3.2 percent).
■ SMI was particularly prevalent among adults living in poverty (9.1 percent) and among those covered by Medicaid/Children's Health Insurance Program (10.7 percent).

Exhibit 1 Percentage of persons aged 18 or older with past year serious mental illness (SMI), by selected characteristics, United States, 2009

NOTES: Serious mental illness (SMI) among adults is defined as persons aged 18 or older who currently or at any time in the past year had a diagnosable mental, behavioral, or emotional disorder and resulting in substantial impairment in carrying out major life activities. Respondents could indicate multiple types of health insurance. CHIP is the Children's Health Insurance Program. Individuals aged 19 or younger are eligible for this plan. See Table 1 for more detail on the constructs included in this exhibit.

SOURCE: National Survey on Drug Use and Health, 2009, Substance Abuse and Mental Health Services Administration, Office of Applied Studies.

Exhibit 1 is a bar chart showing the percentages of persons aged 18 or older with past year serious mental illness (SMI) by selected characteristics in the United States in 2009. The total percentage of persons with SMI is 4.8%. Percentage of persons 18 to 25 years old is 7.3%. Percentage of persons 26 to 49 years old is 5.9%. Percentage of persons 50 years or older is 2.8%. Percentage of males is 3.2%. Percentage of females is 6.4%. Percentage of whites is 5.3%. Percentage of blacks or African Americans is 3.7%. Percentage of Hispanics or Latinos is 4.0%. Percentage of poor is 9.1%. Percentage of near poor is 6.1%. Percentage of not poor is 3.7%. Percentage of people with private health insurance coverage is 3.5%. Percentage of people with Medicaid/CHIP insurance coverage is 10.7%. Percentage of people with other health insurance coverage is 4.0%. Percentage of people with no health insurance coverage is 6.5%.

### National Trends in Past 30-Day Incidence of Serious Psychological Distress among Adults

National levels of psychological distress in adults have remained relatively stable for more than a decade.

The National Health Interview Survey (NHIS) includes a measure to assess recent signs of adult mental health problems and is the only national survey that has provided an annual estimate of adult mental health status for more than a decade. NHIS is the leading survey to provide health estimates for the U.S. civilian noninstitutionalized population, including interviews in more than 33,000 households annually. The presence of the NHIS mental health indicator, serious psychological distress (SPD) in the past 30 days, allows for the examination of trends in U.S. adult mental health status over time. An indicator of recent SPD within NHIS also allows estimates that demonstrate the relationship of recent psychological distress to other health problems. SPD is not a diagnosis; rather, it refers to the presence of mental health symptoms in the past month that may negatively affect a person's ability to participate in family, community, and work life. Exhibit 2 examines rates of SPD in the past 30 days for adults from 1997 to 2009. The exhibit shows the following:

■ In 2009, 3.2 percent of adults aged 18 or older experienced SPD during the past 30 days.
■ National levels of past 30-day SPD among U.S. adults have remained relatively stable for more than a decade. The annual percentage of adults who experienced SPD during the past 30 days ranged from 2.4 percent in 1999 to 3.3 percent in 1997.
■ Estimates of SPD in this exhibit should not be directly compared with the estimates of serious mental illness (SMI) in Exhibit 1. The two constructs, SPD and SMI, are measured differently. SPD is assessed by responses to a short screening measure focused on the presence of mental health symptoms in the past 30 days, whereas SMI is defined by measures to assess both symptoms and their resulting serious functional impairment in the past year.

Exhibit 2 National trends in past 30-day serious psychological distress (SPD) for persons aged 18 or older, United States, 1997–2009

NOTES: Serious psychological distress (SPD) is defined as the presence of mental health symptoms in the past month that may negatively affect a person's ability to participate in family, community, and work life. See Table 6 for more detail on the constructs included in this exhibit.

SOURCE: National Health Interview Survey, 1997–2009, Centers for Disease Control and Prevention, National Center on Health Statistics.

Exhibit 2 is a line graph showing national trends in past 30-day serious psychological distress (SPD) for persons aged 18 or older in the United States from 1997 to 2009. 1997 is 3.3%. 1998 is 3.0%. 1999 is 2.4%. 2000 is 2.7%. 2001 is 3.2%. 2002 is 3.0%. 2003 is 3.1%. 2004 is 3.1%. 2005 is 3.0%, 2006 is 3.0%. 2007 is 2.7%. 2008 is 3.1%. 2009 is 3.2%.

### Co-Occurring Serious Mental Illness and Substance Dependence or Abuse among U.S. Adults

In 2009, more than one quarter of adults with SMI had co-occurring substance dependence or abuse.

The association between mental illness and substance abuse or dependence is well established (SAMHSA, 2010). Co-occurrence of serious mental illness (SMI) with substance dependence or abuse is especially common. The National Survey on Drug Use and Health (NSDUH), a nationally representative survey of the civilian, noninstitutionalized population of the United States aged 12 or older, asks questions that assess the co-occurrence of mental illness and substance use disorders. Exhibit 3 examines the prevalence of co-occurring SMI and substance dependence or abuse in the past year. This exhibit shows the following:

■ In 2009, more than one quarter (25.7 percent) of adults with SMI had co-occurring substance dependence or abuse, related to either illicit drugs or alcohol.
■ Regardless of SMI status, alcohol dependence or abuse was more common than illicit drug dependence or abuse.
■ Adults with SMI were more likely to have any substance dependence in the past year (25.7 percent) than those without any mental illness (6.5 percent).

Exhibit 3 Percentage of persons aged 18 or older with past year serious mental illness (SMI) or no mental illness, by past year substance dependence or abuse, United States, 2009

NOTES: Serious mental illness (SMI) among adults is defined as persons aged 18 or older who currently or at any time in the past year had a diagnosable mental, behavioral, or emotional disorder and resulting in substantial impairment in carrying out major life activities.

No mental illness includes adults who did not meet the criteria for any mental illness in the past year.

Substance abuse and dependence are broad categories associated with a pattern of substance use that leads to clinically significant impairment. Abuse may include symptoms such as failure to fulfill major role obligations, legal problems, use in situations that are physically hazardous, and continued use despite persistent social or interpersonal problems. Substance dependence symptoms may include drug taking in larger amounts than intended, inability to cut down on drug use, a great deal of time spent on activities necessary to obtain the drug, and continued use despite knowledge of health or social problems caused by the drug. See Table 13 for more details on the constructs in this exhibit.

SOURCE: National Survey on Drug Use and Health, 2009, Substance Abuse and Mental Health Services Administration, Office of Applied Studies.

Exhibit 3 is a bar chart showing the percentages of persons aged 18 or older with past year serious mental illness (SMI) or no mental illness by past year substance dependence or abuse in the United States in 2009. 25.7% of persons with past year SMI had illicit drug and/or alcohol dependence or abuse. 6.5% of persons with no mental illness had illicit drug and/or alcohol dependence or abuse. 11.6% of persons with past year SMI had illicit drug dependence or abuse only. 1.4% of persons with no mental illness had illicit drug dependence or abuse only. 20.4% of persons with past year SMI had alcohol dependence or abuse only. 5.7% of persons with no mental illness had alcohol dependence or abuse only.

### Mental Health Disorders among Children

One out of eight U.S. children has a mental health disorder.

Many U.S. children experienced some form of mental health disorder in the past year. Using a sample drawn from several years of the National Health and Nutrition Examination Surveys (NHANES), a recently published study by Merikangas et al. (2010) reported results of parent and child mental health diagnostic interviews. NHANES is a nationally representative probability sample of noninstitutionalized U.S. children aged 8 to 15 who were evaluated in person at mobile examination survey centers. This particular study included 3,042 participants aged 8 to 15 who had participated in one of the NHANES surveys between 2001 and 2004. Select mental health disorders were assessed, including generalized anxiety disorder, panic disorder, eating disorders, depressive disorders, attention deficit hyperactivity disorder (ADHD), and conduct disorders. The study provides aggregate annual estimates of any childhood mental health disorder in the past year as well as the subset of these disorders that caused severe impairment to a child's ability to function at home, at school, in the community, or with peers. This study provides the most up-to-date national prevalence estimates of specific childhood mental health disorders within a sample that includes both school-age children and youth.

According to recent findings from Merikangas et al. (2010), approximately one out of eight U.S. children (13.1 percent) had one of the assessed mental health disorders in the past year. The most common are ADHD, mood disorders, and conduct disorders. Exhibit 4 provides national estimates of mental health disorders in the general population of U.S. children aged 8 to 15. The study found the following:

■ One of eight children aged 8 to 15 (13.1 percent) met the criteria for any mental health disorder in the past year; 11.3 percent met the criteria for a mental health disorder with severe impairment in the past year.
■ Boys had a higher rate of any past year disorder than girls. This was primarily driven by the high rate of ADHD in boys. Girls, on the other hand, had higher rates of mood disorders than boys.
■ For most disorders, there was only a minimal difference between the prevalence of any mental health disorder and the prevalence of any mental health disorder with severe impairment.

Exhibit 4 Percentage of persons aged 8 to 15 with any mental disorder and any disorder with severe impairment in the past year, by sex and age group, United States, 2001–2004

NOTES: Mental disorders were assessed using a structured diagnostic interview that contained modules. Disorder with severe impairment indicates two intermediate ratings or one severe rating on the six impairment questions within a diagnostic module. See Table 9 for more details on the constructs in this exhibit.

SOURCE: Merikangas, K. R., He, J.-P., Brody, D., Fisher, P. W., Bourdon, K., & Koretz, D. S. (2010). Prevalence and treatment of mental disorders among US children in the 2001–2004 NHANES. Pediatrics, 125(1), 75–81.

Exhibit 4 is a bar chart showing the percentage of persons aged 8 to 15 with any mental disorder and any disorder with severe impairment in the past year by sex and age group in the United States from 2001 to 2004. Total persons aged 8 to 15 with any disorder is 13.1%. Total persons aged 8 to 15 with any disorder with severe impairment is 11.3%. Males aged 8 to 15 with any disorder is 14.5%. Males aged 8 to 15 with any disorder with severe impairment is 13.0%. Females aged 8 to 15 with any disorder is 11.6%. Females aged 8 to 15 with any disorder with severe impairment is 9.4%. Persons aged 8 to 11 with any disorder is 12.8%. Persons aged 8 to 11 with any disorder with severe impairment is 11.0%. Persons aged 12 to 15 with any disorder is 13.4%. Persons aged 12 to 15 with any disorder with severe impairment is 11.5%.

### Suicide Rates among Children and Adults by Sex

In 2007, more than 34,000 deaths in the United States resulted from suicide. Males were much more likely than females to die from suicide.

For more than two decades, the National Vital Statistics System has included detailed data on deaths and death rates for the U.S. population aged 5 to 85 or older. From 2000 to 2007, the age-adjusted death rate for suicide increased by 8.6 percent (Xu, Kochanek, Murphy, & Tejada-Vera, 2010). Exhibit 5 shows the number of deaths resulting from suicide for every 100,000 people in the United States by sex from 1985 to 2007. This exhibit shows the following:

■ In 2007, there were 11.3 suicides per 100,000 individuals in the U.S. population.
■ Of the 2,423,712 deaths reported in the United States in 2007, 34,598 deaths resulted from suicide.
■ The annual estimates of U.S. death rates resulting from suicide ranged from 10.4 per 100,000 individuals in 2000 to 12.5 per 100,000 in 1985.
■ Suicide death rates are consistently higher among males than females. In 2007, 18.4 deaths per 100,000 U.S. males were due to suicide, compared with 4.7 deaths per 100,000 U.S. females.

Exhibit 5 Age-adjusted death rates for suicide, by sex, United States, selected years 1985–2007

NOTE: Age-adjusted rates per 100,000 U.S. standard population. See Table 16 for more details on the constructs in this exhibit.

SOURCES: 1985–1995 data with age-adjusted rates obtained from National Vital Statistics System, Centers for Disease Control and Prevention, National Center for Health Statistics.

Xu, J. Q., Kochanek, K. D., Murphy, S. L., & Tejada-Vera, B. (2010). Deaths: Final data for 2007. National Vital Statistics Reports, 58(19). Hyattsville, MD: National Center for Health Statistics.

Exhibit 5 is a line graph showing age-adjusted death rates for suicide by sex in the United States during selected years from 1985 to 2007. 1985 total age-adjusted death rate is 12.5%. 1990 total age-adjusted death rate is 12.5%. 1995 total age-adjusted death rate is 11.8%. 2000 total age-adjusted death rate is 10.4%. 2005 total age-adjusted death rate is 10.9%. 2007 total age-adjusted death rate is 11.3%. 1985 age-adjusted death rate for females is 5.3%. 1990 age-adjusted death rate for females is 4.9%. 1995 age-adjusted death rate for females is 4.3%. 2000 age-adjusted death rate for females is 4.0%. 2005 age-adjusted death rate for females is 4.4%. 2007 age-adjusted death rate for females is 4.7%. 1985 age-adjusted death rate for males is 21.1%. 1990 total age-adjusted death rate for males is 21.5%. 1995 age-adjusted death rate for males is 20.3%. 2000 age-adjusted death rate for males is 18.1%. 2005 age-adjusted death rate for males is 18.0%. 2007 age-adjusted death rate for males is 18.4%.

## 2.3 References

Goldsmith SK, Pellmar TC, Kleinman AM, Bunney WE, editors. 2002. Reducing suicide: A national imperative. Washington, DC. The National Academies Press.
Institute of Medicine. 2010. Returning home from Iraq and Afghanistan: Preliminary assessment of readjustment needs of veterans, service members, and their families. Washington, DC. The National Academies Press.
Katon W. The impact of depression on workplace functioning and disability costs. American Journal of Managed Care. 2009;15(11 Suppl):S322-S327. [pmid: 20088628].
Kuehn BM. Mental health courts show promise. Journal of the American Medical Association. 2007;297(15):1641-1643. [pmid: 17440135].
Merikangas KR, He JP, Brody D, Fisher PW, Bourdon K, Koretz DS. Prevalence and treatment of mental disorders among US children in the 2001–2004 NHANES. Pediatrics. 2010;125(1):75-81. [pmid: 20008426].
Najt P, Fusar-Poli P, Brambilla P. April. 30. Co-occurring mental and substance abuse disorders: A review of the potential predictors and clinical outcomes. Psychiatry Research. 2011;186(2–3):159-164. [pmid: 20728943].
Substance Abuse and Mental Health Services Administration (SAMHSA), SAMHSA Co-Occurring Center for Excellence. 2007. Services integration, overview paper 6. Rockville, MD. SAMHSA. Retrieved from http://store.samhsa.gov/shin/content//SMA07-4294/SMA07-4294.pdf.
Substance Abuse and Mental Health Services Administration (SAMHSA). 2010. Results from the 2009 National Survey on Drug Use and Health: Volume I Summary of national findings. (DHHS Publication No. SMA 10-4856, NSDUH Series H-38A). Rockville, MD. SAMHSA, Office of Applied Studies.
Substance Abuse and Mental Health Services Administration (SAMHSA). 2011. Leading change: A plan for SAMHSA's roles and actions 2011–2014. (DHHS Publication No. SMA 11-4629). Rockville, MD. SAMHSA. Retrieved from http://store.samhsa.gov/product/SMA11-4629.
Vincent GK, Velkoff VA. 2010. The next four decades The older population in the United States: 2010 to 2050. (P25-1138). Current Population Reports. Washington, DC. U.S. Census Bureau. Retrieved from http://www.census.gov/prod/2010pubs/p25-1138.pdf.
Xu JQ, Kochanek KD, Murphy SL, Tejada-Vera B. Deaths: Final data for 2007. National Vital Statistics Reports. 2010;58(19). Hyattsville, MD. National Center for Health Statistics.