# INTRODUCTION

## 1.1 The Mental Health, United States Series

For more than 25 years, the Mental Health, United States series has presented nationwide measures of mental health. Published biannually by the Substance Abuse and Mental Health Services Administration (SAMHSA), the volume serves as the Nation's most comprehensive resource for mental health statistics. The data provide timely insights into the population's mental health status, the provision of mental health treatment, and funding for that treatment in the United States.

## 1.2 Organization

This volume is organized into seven sections. Section 1 provides an introduction to the report and an overview of the current policy context relevant to the U.S. mental health service delivery system. Sections 2 through 5 present background information and exhibits pertinent to the mental health of the population, providers and settings, payers and payment mechanisms, and States, respectively. Section 6, Data Gaps, identifies key areas in which only limited information is available and for which further study may be indicated. Examples of gaps include the need for data that track the incidence and prevalence of mental illness, as well as the recovery process, and detailed estimates on the mental health of certain vulnerable populations, particularly children. Section 7 presents tables with detailed population, provider, payment mechanism, and State estimates.

## 1.3 New Features

In addition to updating the data from Mental Health, United States, 2008, the 2010 volume contains a number of new features:

■ State-level data. Perhaps the most significant addition is the State-level estimates section, which addresses the need for State-level data to inform day-to-day decisions on budgeting, planning, and care provision. Many of these tables and exhibits draw from SAMHSA's National Survey on Drug Use and Health (NSDUH).
■ Needs of children. A number of tables focus specifically on the needs of and services for children.
■ Impact of State budget crises. Results from a recent survey by NRI Inc. (2011) provide insight into the impact of the budget crises in States on mental health service provision.
■ Services in nontraditional settings. The volume now provides key estimates for clubhouses—a nontraditional setting for nonclinical services—and inmates in Federal, State, and local facilities.
■ Treatment gap. A number of tables consolidate the existing evidence on treatment availability for people who need mental health services.
■ Data gaps. The volume delineates key gaps in the available mental health data sources used as a basis for estimates to note potential areas for further study.

## 1.4 Policy Environment

The data from Mental Health, United States should be put into context before use. The policy environment will have influenced the data presented here, and the data in this volume also may influence the outcome of current policy and the formation of future policy. The mental health policy environment is currently dominated by the interconnected topics of health care reform, mental health parity, changes to Federal mental health block grants to States, and the economic recession.

Although several piecemeal reforms to the mental health and general health care system have occurred in recent years, health care reform legislation passed in 2010 is likely to have a profound effect on the treatment and financing of mental health. Based on two legislative acts in 2010—the Patient Protection and Affordable Care Act (Public Law 111-148) and the Health Care and Education Reconciliation Act of 2010 (Public Law 111-152), together referred to as the Affordable Care Act (ACA)—reform likely will change the provision of mental health care in numerous ways. Perhaps the most relevant changes are as follows:

■ In 2010, adults with preexisting conditions were given access to insurance through a temporary, high-risk insurance pool called the Pre-Existing Condition Insurance Plan.
■ In 2010, the age limit at which children could be covered by their parents' insurance was raised from age 22 to age 26.
■ In 2011, out-of-pocket spending on prescription medication will be limited.
■ In 2014, Medicaid will be expanded to cover an estimated 16 million individuals who were not covered previously and with incomes at or below 133 percent of the Federal poverty level (FPL) (Ku, 2010). Medicaid currently covers select groups of people with lower incomes and with disabilities and pays for about 28 percent of all mental health spending (SAMHSA, 2010a).
■ In 2014, people ineligible for Medicaid and with incomes up to 400 percent of FPL will be allowed to receive premium subsidies through tax credits for health plans offered through State health insurance exchanges. These exchanges will be new entities that will reorganize the insurance market for health insurance—for example, by coordinating private insurance and Medicaid plans—and offer a choice of plans (HealthCare.gov, 2011).
■ In 2014, Medicaid will cover medication such as barbiturates, benzodiazepines, and smoking cessation medications.

Historically, third-party coverage for treatment for behavioral health needs placed a greater burden on consumers than treatment for general medical needs. In recent years, this lack of parity has been addressed incrementally by different States and by the Federal government using various pieces of legislation, such as the Mental Health Parity Act of 1996 and the Mental Health Parity and Addiction Equity Act of 2008 (MHPAEA). This legislation should help improve access to care for people with mental illness (SAMHSA, 2010b). Moreover, as private and public coverage is expanded by health care reform, the impact of parity legislation will deepen because this legislation applies to people with existing coverage and those who are newly covered.

Since the move toward deinstitutionalization that began in the late 1960s, most mental health care has been provided in community settings (Frank & Glied, 2006). The main way by which the Federal government helps provide community-based mental health services for adults and children is through the Community Mental Health Services Performance Partnership Block Grant (CMHSPPBG) administered by SAMHSA. SAMHSA is working with States to change the block grant application, reporting, and planning requirements, starting with 2012 funding. The changes are intended to reduce the application burden on States and will likely direct funding to support people with gaps in coverage, cover treatment and support services not covered by third-party insurance, fund prevention activities, and collect data to assist in treatment planning (SAMHSA, 2011a, 2011b). With this flexibility, States may be able to target block grant funds toward needed wraparound services—such as employment or housing—that are not covered by third-party health insurance.

The economic recession in the United States and ongoing budget crises in many States have far-reaching policy implications for mental health because States play a particularly important role in underwriting mental health care provision. In 2005, State and local sources accounted for almost 20 percent of all mental health spending, whereas they accounted for 6 percent of spending on all health conditions (SAMHSA, 2010a). The impact on care is likely quite widespread. For example, a recent survey indicates that nearly 3,000 State psychiatric beds were closed in 2009 and 2010 and that 16 States and the District of Columbia planned to close State psychiatric hospital beds in the future (NRI Inc., 2011). Any requirements that health reform places on States in the future may further challenge State budgets. People who rely on State mental health resources may be in particular jeopardy, because they also often rely on other services through State-funded sources, such as those providing education, criminal justice, or housing.

## 1.5 Summary

This volume of Mental Health, United States provides a broad perspective on many complex components of the Nation's mental health system. The volume includes updated data with an increased focus on State-level estimates, children, mental health treatment in nontraditional settings, and levels of unmet mental health needs.

The face of the U.S. mental health service delivery system is changing. This is a period of tremendous financial pressure on State and federally sponsored programs, accompanied by the potential for unprecedented reform to the health care delivery system. Ongoing monitoring and research efforts must keep up with shifts in the U.S. population size and diversity; these efforts also must monitor the impact of policy changes and budget crises on the Nation's mental health service array and financing structures.

## 1.6 References

Frank RG, Glied SA. 2006. Better but not well: Mental health policy in the United States. Baltimore, MD. Johns Hopkins University Press.
Ku L. Ready, set, plan, implement: Executing the expansion of Medicaid. Health Affairs. 2010;29(6):1173-1177. [pmid: 20530350].
HealthCare.gov. 2011. Coming in 2014: Affordable insurance exchanges. Retrieved from http://www.healthcare.gov/law/provisions/exchanges/index.html.
NRI Inc. 2011. State Mental Health Agency Budget Reductions Survey. Falls Church, VA. NRI Inc.
Substance Abuse and Mental Health Services Administration (SAMHSA). 2010. National expenditures for mental health services and substance abuse treatment, 1986–2005. (DHHS Publication No. SMA 10-4612). Rockville, MD. Center for Mental Health Services and Center for Substance Abuse Treatment, SAMHSA.
Substance Abuse and Mental Health Services Administration (SAMHSA). Parity: Landmark legislation takes effect. What are the implications for millions of Americans?. SAMHSA News. 2010;18(1):1-2.
Substance Abuse and Mental Health Services Administration (SAMHSA). 2011. SAMHSA FY 2012–2013 block grant application, frequently asked questions. Retrieved from http://www.samhsa.gov/grants/blockgrant/BG_FAQS_05-24-11.pdf.
Substance Abuse and Mental Health Services Administration (SAMHSA). 2011. SAMHSA news release: SAMHSA introduces guidance changing its block grant programs to reflect new opportunities provided by parity, health reform and emerging science. Retrieved from http://www.samhsa.gov/newsroom/advisories/1104110222.aspx.