# MENTAL HEALTH, UNITED STATES, 2010 EXPERT ADVISORY PANEL

The structure and content of the report were guided by the suggestions of an Expert Advisory Panel that was convened on February 24, 2010:

Panel Member | Affiliation
Amy Bernstein | Centers for Disease Control and Prevention
William Clark | Centers for Medicare & Medicaid Services
Lisa Colpe | National Institute of Mental Health
John Drabek | Assistant Secretary for Planning and Evaluation, HHS
William Gardner | Nationwide Children's Hospital
Olinda Gonzalez | SAMHSA
Kevin Martone | New Jersey Department of Human Services
Joseph Morrissey | University of North Carolina at Chapel Hill
Alexander Ross | Health Resources and Services Administration
David Shern | Mental Health America
Shawn Terrell | Office on Disability, HHS
Virginia Trotter Betts | Department of Mental Health and Developmental Disabilities
Mohini Venkatesh | National Council for Community Behavioral Healthcare
Samuel Zuvekas | Agency for Healthcare Research and Quality