# EXECUTIVE SUMMARY

Mental Health, United States, 2010 is the most recent edition of a publication issued by the Substance Abuse and Mental Health Services Administration (SAMHSA) of the U.S. Department of Health and Human Services biannually since 1980. The current volume serves as a comprehensive resource for mental health statistics at the national and State levels; it draws information from 35 different data sources and includes more than 25 exhibits and 130 tables. The volume presents national-level estimates on (1) the mental health of the population, (2) providers and settings for mental health services, and (3) payers and payment mechanisms. In addition, the 2010 volume presents State-level estimates of the mental health of each State's population, as well as provider and payment mechanisms for mental health services at this level.

The 2010 edition of Mental Health, United States provides mental health statistics using the most recent data available. This edition also includes several new tables that provide expanded information on some special populations of interest, such as children and members of the military; mental health service provision in nontraditional settings, such as the use of clubhouses to help integrate people with mental illness into the community; and estimates particularly relevant to States, such as the impact of the recent budget crisis on service provision.

This volume is organized into seven sections. Section 1 provides an introduction to the report and an overview of the current policy context relevant to the U.S. mental health service delivery system. Sections 2 through 5 present background information and exhibits pertinent to the mental health of the population, providers and settings, payers and payment mechanisms, and States, respectively. Section 6, Data Gaps, identifies key areas in which only limited information is available and for which further study may be indicated. Examples of gaps include the need for data that track the incidence and prevalence of mental illness, as well as the recovery process, and detailed estimates on the mental health of certain vulnerable populations, particularly children. Section 7 presents tables with detailed population, provider, payment mechanism, and State estimates.

The following are highlights of the data presented in Mental Health, United States, 2010:

## 1 Mental Health of the Population

■ Approximately 11 million U.S. adults (4.8 percent) had serious mental illness (SMI) in 2009.
■ More than one quarter of adults with SMI also had co-occurring substance dependence or abuse in 2009.
■ During the 2001–2004 period, one out of eight U.S. children aged 8 to 15 (or 13.1 percent) had a mental health disorder in the past year.
■ In 2007, more than 34,000 deaths in the United States were due to suicide.

## 2 Providers and Settings for Mental Health Services

■ In 2009, more than one in eight U.S. adults received some type of mental health treatment in the past year.
■ During the 2001–2004 period, more than half of all children with a mental health disorder received treatment in a hospital, clinic, or office within the past year.
■ In 2009, 40 percent of adults with SMI reported not receiving any treatment.
■ From 1996 to 2008, medication fills have increased considerably for mental health and/or substance abuse conditions. The categories of medication with the greatest growth have been antidepressant medications for adults and stimulant medications for children.

## 3 Payers and Payment Mechanisms

■ Although mental health expenditures have increased (from $32 billion in 1986 to $132 billion in 2005), they have fallen as a share of all health expenditures (from 7.2 percent in 1986 to 6.1 percent in 2005).
■ In 2005, public sources of coverage—such as Medicaid—accounted for more than 50 percent of all mental health expenditures.
■ From 1986 to 2005, spending on prescription medications increased faster than any other type of mental health care.

## 4 States: People, Providers, and Payers

■ During the 2005–2009 period, State-specific prevalence of past year major depressive episodes ranged from 5.2 to 9.5 percent in adults and 6.8 to 10.3 percent in youth aged 12 to 17.
■ During the 2005–2009 period, State-specific utilization rates of outpatient specialty mental health treatment ranged from 3.0 to 9.5 percent for adults and from 8.0 to 16.9 percent for youth aged 12 to 17.
■ States with a large proportion of the population living in rural areas have greater shortages of mental health professionals than States with a large proportion of the population living in urban areas.

The scope of the next volume in the series, Behavioral Health, United States, 2012, will be broadened to include information on substance use disorders, which co-occur frequently with mental health disorders. This larger perspective on behavioral health will help strengthen the series' utility as a key resource for decision making in a changing and challenging health care landscape.