# MEDICATION LISTS

This appendix lists the mental health and/or substance abuse medications for each medication class presented in Exhibits 9, 13, 19, and 20 and in Tables 30, 31, 62, 63, 95, and 96.

Medications for Mental Health Disorders

Antianxiety, Sedative, Hypnotic
Alprazolam | Diazepam | Methylprylon
Amobarbital | Droperidol | Oxazepam
Amobarbital-Secobarbital | Estazolam | Pentobarbital
Buspirone | Ethchlorvynol | Phenobarbital
Butabarbital | Flurazepam | Prazepam
Butalbital | Glutethimide | Quazepam
Chloral hydrate | Halazepam | Secobarbital
Chlordiazepoxide | Hexobarbital | Temazepam
Chlordiazepoxide-Clidinium | Hydroxyzine | Triazolam
Chlormezanone | Lorazepam | Zaleplon
Clonazepam | Mephobarbital | Zolpidem
Clorazepate | Meprobamate

Antidepressant
Amitriptyline | Duloxetine | Nortriptyline
Amitriptyline-Chlordiazepoxide | Escitalopram | Paroxetine
Amoxapine | Fluoxetine | Phenelzine
Bupropion | Fluvoxamine | Protriptyline
Citalopram | Imipramine | Sertraline
Clomipramine | Isocarboxazid | Tranylcypromine
Desipramine | Maprotiline | Trazodone
Desvenlafaxine | Mirtazapine | Trimipramine
Doxepin | Nefazodone | Venlafaxine

Antimanic or Anticonvulsant
Carbamazepine | Lithium | Topiramate
Divalproex sodium | Oxcarbazepine | Valproate
Gabapentin | Tiagabine | Valproic acid
Lamotrigine

Antipsychotic
Amitriptyline-Chlordiazepoxide | Mesoridazine | Quetiapine
Amitriptyline-Perphenazine | Methotrimeprazine | Risperidone
Aripiprazole | Molindone | Thioridazine
Chlorpromazine | Olanzapine | Thiothixene
Clozapine | Paliperidone | Trifluoperazine
Fluoxetine-Olanzapine | Perphenazine | Triflupromazine
Fluphenazine | Pimozide | Ziprasidone
Haloperidol | Prochlorperazine
Loxapine | Promazine

Stimulant
Amphetamine | Lisdexamfetamine | Methylphenidate
Amphetamine-Dextroamphetamine | Extroamphetamine | Modafinil
Atomoxetine | Methamphetamine | Pemoline
Dexmethylphenidate

Medications for Substance Use Disorders

Acamprosate | Disulfiram | Naltrexone
Buprenorphine | Methadone

Medications for Alzheimer's Disease

Donepezil | Memantine | Rivastigmine
Galantamine | Physostigmine | Tacrine

SOURCE: National Institute on Mental Health. 2011. Mental health medications. Retrieved from http://www.nimh.nih.gov/health/publications/mental-health-medications/alphabetical-list-of-medications.shtml.