# ADDITIONAL ACKNOWLEDGMENTS

The following people contributed to this edition of Mental Health, United States: Alexander Cowell (project director), Heather Ringeisen, Leyla Stambaugh, David Kaiser, Natalie Hodges, Justin Landwehr, and Valerie Hoffman (RTI International); Tami Mark, Elizabeth Stranges, and Katharine Levit (Thomson Reuters); Dominic Hodgkin and Elizabeth Merrick (Brandeis University); Ted Lutterman (NRI Inc.); Barbara Burns and Marvin Swartz (Duke University); and Carla Linkous (Cloudburst Consulting Group).

Additionally, a number of individuals prepared and contributed data that were crucial to the completion of Mental Health, United States, 2010: Anita Bercovitz (National Center for Health Statistics), Donald Cherry (National Center for Health Statistics), Joseph Gfroerer (CBHSQ), Lauren Glaze (Bureau of Justice Statistics), Sarra Hedden (CBHSQ), Art Hughes (CBHSQ), Michael Jones (CBHSQ), Colleen McKay (Center for Mental Health Services Research, University of Massachusetts Medical School), Laura Milazzo-Sayre (CBHSQ), Ryan Mutter (Agency for Healthcare Research and Quality), Catherine Simile (National Center for Health Statistics), Mark Smith (Veterans Health Administration), Peter Tice (CBHSQ), and Samuel Zuvekas (Agency for Healthcare Research and Quality).

The following individuals served as external reviewers for the volume: Lisa Colpe (National Institute of Mental Health), Rachel Garfield (Kaiser Commission on Medicaid and the Uninsured), Darcy Gruttadaro (National Alliance on Mental Illness), Kevin Hennessy (SAMHSA), Chris Koyanagi (Judge David L. Bazelon Center for Mental Health Law), Lisa Patton (Assistant Secretary for Planning & Evaluation, HHS), Marvin Swartz (Duke University), Mohini Venkatesh (National Council for Community Behavioral Healthcare), and Capt. Elise Young (Health Resources and Services Administration).

Finally, particular recognition is due to Marceline Murawski, Susan Murchie, Pamela Prevatt, and E. Andrew Jessup, along with other members of the publications staff at RTI International, who provided expert editorial services.