# References

Annexure J, Katon W, Sullivan M, Miranda J. The effectiveness of treatments for depressed older adults in primary care. Paper presented at Exploring Opportunities to Advanced Mental Health Care for an Aging Population, sponsored by the John A. Hartford Foundation, Rockville, MD, 1997.
Borowsky SJ, Rubenstein LV, Meredith LS, Camp P, Jackson-Triche M, Wells, KB Who is at risk of nondetection of mental health problems in primary care? J Gen Intern Med 2000 15(6):381 8 10886472 1495467
Coyne JC, Fechner-Bates S, Schwenk TL Prevalence, nature and comorbidity of depressive disorders in primary care Gen Hosp Psychiatry 1994 9(4):267 76
Department of Health and Human Services (DHHS). Mental Health: A Report of the Surgeon General. Rockville, MD: U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration, Center for Mental Health Services, National Institutes of Health, National Institute of Mental Health, 1999.
Higgins ES A review of unrecognized mental illness in primary care Prevalence, natural history, and efforts to change the course. Arch Fam Med 1994 310908 17
Katon W, Schulberg H Epidemiology of depression in primary care Gen Hosp Psychiatry 1992 144237 47 1505745
Malek SP. Financial, risk and structural issues related to the integration of behavioral health care in primary care settings under managed care. Research report published by Milliman & Robertson, Inc., 1999.
Millis JS. The Graduate Education of Physicians. Report of the Citizens' Commission on Graduate Medical Education. Chicago: American Medical Association, 1966.
Murray CJL, Lopez AD (Eds.). The global burden of disease. Comprehensive assessment of mortality and disability from diseases, injuries, and risk factors in 1990 and projected to 2020. Cambridge, MA: Harvard School of Public Health, 1996.
Olfson M, Fireman B, Weissman MM, Leon AC, Sheehan DV, Kathol RG, Hoven C, Farber L Mental disorders and disability among patients in a primary care group practice Am J Psychiatry 1997 154121734 40 9396954
Peterson B, West J, Tanielian T, Pincus H. In RW Manderscheid, MJ Henderson (Eds.), Mental Health United States. 1998 (pp. 14-246). Rockville, MD: U.S. Department of Health and Human Services, Center for Mental Health Services.
Regier DA, Narrow WE, Rae DS, Manderscheid RW, Locke BZ, Goodwin FK The de facto US mental and addictive disorder system: Epidemiologic Catchment Area prospective 1-year prevalence rates of disorders and services Arch Gen Psychiatry 1993 50(2):85 94 8427558
Rost KM, Zhang M, Fortney J, et. al Persistently poor outcomes of undetected major depression in primary care Gen Hosp Psychiatry 1998 20112 20 9506250
Schulberg HC, Katon WJ, Simon GE, Rush AJ Best clinical practice: guidelines for managing major depression in primary medical care J Clin Psychiatry 1999 60Suppl 719 26 10326871
Sherbourne CD, Jackson, CA, Meredith LS, Camp P., Wells KB Prevalence of comorbid anxiety disorders in primary care outpatients Arch Fam Med 1996 5127 34 8542051
Wells KB, Sherbourne C, Schoenbaum M, Duan N, Meredith L, Annexure J, Miranda J, Carney MF, Rubenstein LV Impact of disseminating quality improvement programs for depression in managed primary care: a randomized controlled trial JAMA 2000 2832212 20 10634337
Williams JW, Rost K, Dietrich AJ, Ciotti MC, Zyzanski SJ, Cornell J Primary care physicians' approach to depressive disorders: effects of physician specialty and practice structure Arch of Fam Med 1999 8158 67 9932074