# Acknowledgements

This report was prepared by the Department of Health and Human Services. It is an outgrowth of Mental Health: A Report of the Surgeon General, which was released in December 1999.

Planning Committee

Chair Kate Godfried, J.D., M.S.P.H

Coordinating Editors Irene Stith-Coleman, Ph.D. Ann L. Elderkin, P.A.

Science Writer Miriam Davis, Ph.D.

Members Bernard Arons, M.D. Elaine Baldwin, M.Ed. Eric Goplerud, Ph.D. Nicole Lurie, M.D., M.S.P.H. Beverly Malone, Ph.D., R.N., F.A.A.N. Ron Manderscheid, Ph.D. Harriet G. McCombs, Ph.D. Charlotte Mullican, B.S.W., M.P.H. Rochelle Rollins, Ph.D. Marc Safran, M.D., F.A.C.P.M. Frank Sullivan, Ph.D. Bertha Williams, M.S., R.N.

Other Contributors Camille Barry, Ph.D., R.N. Helen Burstin, M.D., M.P.H. Junius Gonzales, M.D. Kevin Hennessy, Ph.D. Brenda Reiss-Brennan, M.S., A.P.R.N., C.S.

Special thanks to the leadership and staff of the Office of Public Health and Science for their enthusiastic support of this interdepartmental effort.

RADM Kenneth P. Moritsugu, M.D., M.P.H., Deputy Surgeon General, USPHS Nicole Lurie, M.D., M.S.P.H., Principal Deputy Assistant Secretary for Health Beverly L. Malone, Ph.D., R.N., F.A.A.N., Deputy Assistant Secretary for Health