# Recommendations Toward a National Action Strategy

The core principles provided the foundation on which participants were able to build consensus in developing actual strategies that would promote the bridging of primary care and mental health. These strategies were prioritized into the following action strategy recommendations. The recommendations reflect the merging of multistakeholder expert opinions from the fields of practice and research and were put forth as a guide to spawning a national action strategy to promote implementation of evidence-based quality care. Since the Carter Center meeting, this National Action Strategy has undergone further evolution.

1. Convene a group under the auspices of the DHHS to develop a framework for the integration of mental health care and primary care, including a focus on comorbidities, diverse modalities, and diverse populations.
2. Incorporate a list of skills, knowledge, attitudes, and simple tools that reflects evidence-based "best practices" and treatment management, leading to improved outcomes.
3. Design education and training standards for the integration of mental health care and primary health care-with all stakeholders, including accreditation bodies-and promote implementation of those standards by schools of health and behavioral health.
4. Evaluate whether program and policy initiatives on integration lead to the elimination of racial and ethnic health disparities and promote equal access to high-quality health care.
5. Develop a plan for research and demonstration projects on integration that meet basic methodological requirements for generalizability with respect to service delivery models and health outcomes.
  1. Articulate a vision for success for a consumer-driven integrated service delivery system that includes the following: awareness of the culture of primary care, patient education, professional training, follow-up care, and care management.
  2. Bring together multiple private and public funding sources for projects and develop a plan for projects-sustainability, if the projects are found successful.
  3. Convene accreditation and licensure and regulatory agencies to reduce barriers to implementation of research and demonstration projects (e.g., funding and/or regulatory waivers).
  4. Lead to development of initiatives that foster the development of service and economic models with these basic features: (a) collaborative/integrated care among consumers, primary care providers, and mental health specialists to meet local needs; (b) evidence-based approach to care delivery based on scientific methods (e.g., randomized controlled trial, quasi-experimental design, case-control study, survey designs); and (c) measurement of outcomes, such as access, costs, functional status, quality of life, patient/family/provider satisfaction, health beliefs/stigma, relapse reduction, sentinel events, recovery, and the effects of consumer and provider incentives on health outcomes and process measures.