# Meeting Format

The conference agenda was structured around formal presentations, question-and-answer sessions, and small breakout groups for detailed deliberation. Panel presentations and question-and-answer sessions furnished a common understanding of the nature of the problem, some "real world" programs, the hurdles and opportunities programs face, and findings from research.

Dr. Satcher's speech was followed by a state-of-the-art review of practice and research findings gathered from structured interviews. The structured interviews had been conducted before the meeting by consultant and meeting organizer Brenda Reiss-Brennan, President of Primary Care Family Clinics, Inc. Over 90 interviews were completed of attendees and nonattendees from a diverse group of experts representing business, foundations, federal agencies, consumers and families, research, employers, economists, epidemiologists, providers, health care consultants, and payors. Ms. Reiss-Brennan gave an overview of her findings about participants' level of interest in the process of integration^3^ and their rationale for developing systemic approaches to promoting healthy families and communities.

3 Participants spent a significant amount of time discussing integration but were unable to reach a consensus on a definition for integration.

The interviews indicated that clinical research knowledge appears to be directing the field toward integration and economic knowledge appears to be directing the field away from integration. In the middle of this quality gap, being squeezed to maximum capacity, are providers of care and their patients and families, who attempt to negotiate major health disabilities in stressed environments. This current nonintegrated process of care creates costly burdens for the health care system, the family, and the community.

Interviews revealed consensus among participants to build collaboration and commitment among stakeholders that result in strong leadership, mobilization of successful implementation strategies, and demonstration of affordable, evidence-based integrated care.

After plenary and panel presentations, participants were divided into five breakout groups, covering seminal issues of design, training, economics, research, and quality. The breakout groups were charged with developing ideas for core principles and action steps, and then bringing those ideas forward for general discussion by all participants.

A reporter from each breakout group presented their group's priorities when participants reconvened in a general session. With the aid of a professional facilitator to guide the discussion and build consensus, participants separately voted on their top core principles and action steps.