# Appendix

Participants A Surgeon General's Working Meeting on The Integration of Mental Health Services and Primary Health Care, Held on November 30 - December 1, 2000

## Business / Health Care Systems

- Kris Apgar
- Director
- Washington Business Group on Health
- 50 F Street, N.W.
- Suite 60
- Washington, DC 20001-1566

- Ron I. Dozoretz, M.D.
- Chairman and Chief Executive Officer
- Value Option
- 8614 Westwood Center Drive, Suite 20
- Vienna, VA 22182-2233

- Saul Feldman, M.D., Ph.D.
- Chairman & Chief Executive Officer
- United Behavioral Health
- 425 Market Street, 27th Floor
- San Francisco, CA, 94105-2426

- Gary Gottlieb, M.D., M.B.A.
- Chairman
- Partners Psychiatry and Mental Health System
- Professor of Psychiatry
- Harvard Medical School
- c/o Massachusetts General Hospital
- Bulfinch Building, Suite 370
- 55 Fruit Street
- Boston, MA 02114-2696

- Suzanne Paranjpe, Ph.D.
- Senior Vice President
- Greater Detroit Area Health Council
- Health Information Action Group
- 333 West Fort Street, Suite 150
- Detroit, MI 48226-3156

- Dennis E. Richling, M.D.
- Union Pacific
- 1416 Dodge, Room 90
- Omaha, NE 68179

- Tara Wooldridge , L.C.S.W.
- Manager
- Employee Assistance Program
- Delta Airlines
- 1050 Delta Boulevard
- Atlanta, GA 30320-1989

## Consumer / Patient / Family

- Moe Armstrong, M.B.A., M.A.
- P.O. Box 39081
- Cambridge, MA 02139-0009

- Don Daves
- President
- Board of Directors for NAMI Georgia
- An Affiliate of the National Alliance for the Mentally Ill
- 3125 Presidential Parkway
- Suite 33
- Atlanta, GA 30340-3700

- Carolyn Nava
- Federation of Families for Children's Mental Health
- 1101 King Street, Suite 42
- Alexandria, VA 22314-2944

- Delilah J. Ramirez
- 1150 Syracuse Street
- Building #
- Apartment # 14
- Denver, CO 80220-3242

## Experts

- Elise Berryhill, Ph.D.
- Muscogee (Creek) Nation Behavioral Health Service
- 100 West 7th Street
- Okmulgee, OK 74447-5007

- Virginia Trotter Betts, R.N., J.D., M.S.N., F.A.A.N.
- Associate Director for Health Policy Initiative
- University of Tennesse
- Center for Health Services Research
- 66 North Pauline, Suite 46
- Memphis, TN 38163

- Homer L. Chin, M.D.
- 500 Northeast Multnomah Street
- Suite 10
- Portland, OR 97232-2022

- Allen Dietrich, M.D.
- Chair
- MacArthur Foundation Initiative on Depression and Primary Care
- Dartmouth Medical School
- North College Street
- Hanover, NH 03755

- Lynn Elinson, Ph.D.
- Deputy Director
- National Program on Depression and Primary Care
- University of Pittsburgh, School of Medicine
- Western Psychiatric Institute and Clinic
- 3811 Ohara Street, Room 41
- Pittsburgh, PA 15213-2597

- Richard Frank, Ph.D.
- Professor
- Department of Health Care Policy
- Harvard University
- 180 Longwood Avenue
- Boston, MA 02115-5821

- Greg Fricchione, M.D.
- Director
- The Carter Center Mental Health Program
- Associate Professor of Psychiatry
- Harvard Medical School
- One Copenhil
- 453 Freedom Parkway
- Atlanta, Georgia 30307-1496

- Pablo Hernandez, M.D.
- Administrator
- Wyoming State Commission for Mental Health
- Division of Behavioral Health
- P.O. Box 177
- Evanston, WY 82931

- Dennis Hulet, A.A.A.
- Principal and Healthcare Management Consultant
- Milliman and Robert
- 1301 5th Avenue
- Suite 380
- Seattle, WA 98101-2646

- Brent James, M.D., M.Stat.
- Vice President for Medical Research
- Intermountain Health Care
- 36 South State Street
- Salt Lake City, Utah 84111-1486

- Wayne Katon
- Department of Psychiatry and Behavioral Science
- Box 35656
- University of Washington
- 1959 NE Pacific Street
- Seattle, WA 98195-6560

- Donald R. Lipsitt, M.D.
- Clinical Professor of Psychiatry
- Harvard Medical School
- Medical Director
- Institute for Behavioral Science in Health Care
- 15 Griggs Road
- Brookline, MA 02446-4701

- Anthony Radcliffe, M.D.
- Director of Addiction Medicine
- Kaiser Permanente Southern California
- 740 Buckingham Drive
- Redlands, CA 92374-6421

- Bruce Rollman, M.D., M.P.H.
- Assistant Professor
- Medicine, Psychiatry, and Health Services Administration
- University of Pittsburgh, School of Medicine
- Suite E82
- 2000 Lothrop Street
- Pittsburgh, PA 15213-2582

- Lisa V. Rubenstein, M.D., M.S.P.H.
- Professor in Residence
- University of California at Los Angeles and the Veterans' Administration
- Greater Los Angeles Health Care System
- Director
- Veterans' Administration Health Services Research and Development Center of Excellence for the Study of Health Care Provider Behavior
- Senior Natural Scientist
- Ran
- 1700 Main Street
- Santa Monica, CA 90401-3208

- Dawn Swaby-Ellis, M.D.
- Assistant Professor of Pediatrics
- North DeKalb Health Center
- 3807 Clairmont Road
- Chamblee, GA 30341-4911

- Michael Von Korff, Sc.D.
- Center for Health Studies
- Group Health Cooperative
- 1730 Minor Avenue
- Suite 160
- Seattle, WA 98101

## "Real World" Programs

- David N. Broadbent, M.D., M.P.H.
- Rochester Primary Care N
- 259 Monroe Avenue
- Rochester, New York 10032-3632

- Wayne Cannon, M.D.
- Intermountain Health Care
- 36 South State Street
- Salt Lake City, Utah 84111-1486

- Henry Chung, M.D.
- Medical Director
- Depression /Anxiety Disease Management Team
- Pfizer, Inc.
- 235 East 42nd Street
- 235/10/2
- New York, NY 10017-5755

- J. Sloan Manning, M.D.
- Family Medicine
- 1127 Union Avenue
- Memphis, TN 38104-6646

- Linda Weinreb, M.D.
- Director
- Homeless Families Program
- The Family Health Center
- Department of Family Medicine and Community Health
- University of Massachusetts Medical School
- 55 Lake Avenue North
- Worcester, MA 01655

## Facilitators

- Brenda Reiss-Brennan, M.S., A.P.R.N., C.S.
- President
- Primary Care Family Therapy Clinics, Inc
- 3570 West 9000 South
- Suite 12
- West Jordan, UT 84088-8874

- Miriam Davis, Ph.D
- Medical Writer and Consultant
- 13420 Montvale Drive
- Silver Spring, MD 20904-1232

- Steven Grossman
- Senior Managing Director
- Hill and Knowlto
- 600 New Hampshire Avenue, N.W.
- Suite 601
- Washington, DC 20037-2413

## Core Group

- Bernard Arons, M.D.
- Director
- Center for Mental Health Service
- 5600 Fishers Lane, Room 17-9
- Rockville, MD 20857

- Elaine Baldwin, M.Ed.
- Director
- Constituency Outreach and Education Program
- Office of Communications and Public Liaison
- National Institute of Mental Health
- National Institutes of Health
- 31 Center Drive, Room 4A5
- Bethesda, MD 20892-2475

- Eric Goplerud, Ph.D.
- Associate Administrator for Managed Care
- Substance Abuse and Mental Health Services Administration
- Parklawn Building, Room 10-9
- Rockville, MD 20857

- Kate Gottfried, J.D., M.S.P.H
- Senior Health Policy Advisor
- Office of Public Health and Science
- Office of Disease Prevention and Health Promotion
- Department of Health and Human Services
- 200 Independence Avenue, S.E., Room 738
- Washington, DC 20201

- Nicole Lurie, M.D., M.S.P.H.
- (Then) Principal Deputy Assistant Secretary for Health
- Department of Health and Human Services
- 200 Independence Avenue, S.E., Room 716
- Washington, DC 20201

- Beverly Malone, Ph.D., R.N., F.A.A.N.
- (Then) Deputy Assistant Secretary for Health
- Department of Health and Human Services
- 200 Independence Avenue, S.E., Room 716
- Washington, DC 20201

- Ron Manderscheid, Ph.D.
- Substance Abuse and Mental Health Services Administration
- Center for Mental Health Service
- 5600 Fishers Lane, Room 15C-0
- Rockville, MD 20857

- Harriet G. McCombs, Ph.D.
- Health Resources and Services Administration
- Bureau of Primary Health Care
- 4350 East-West Highway, 11th Floor
- Bethesda, MD 20814

- Charlotte Mullican, B.S.W., M.P.H.
- Department of Health and Human Services
- Agency for Healthcare Research and Quality
- Building 6010, Room 30
- Rockville, MD 20852

- Rochelle Rollins, Ph.D.
- Office of the Director
- Bureau of Primary Health Care
- Health Resources Services Administration, 11th Floor
- 4350 East-West Highway
- Bethesda, MD 20814

- Marc A. Safran, M.D., F.A.C.P.M.
- Chief Medical Officer and Psychiatrist
- Diabetes Program Branch
- Chai
- Mental Health Work Group
- Centers for Disease Control and Prevention
- 4770 Buford Highway (Mail Stop K-10
- Atlanta, GA 30341

- VADM David Satcher, M.D., Ph.D.
- Surgeon General
- (Then) Assistant Secretary for Health and Surgeon General
- Department of Health and Human Services
- 200 Independence Avenue, S.E., Room 716
- Washington, DC 20201

- Frank Sullivan, Ph.D.
- Department of Health and Human Services
- The Health Care Financing Administration
- 7500 Security Blvd
- Mail Stop C4-25-1
- Baltimore, MD 21244-1850

## Foundations

- Andrea Gerstenberger, Sc.D.
- Senior Program Officer
- California Health Care Foundation
- 476 Ninth Street
- Oakland, CA 94607-4048

- Peter Peccora
- Casey Family Program
- 1300 Dexter Avenue North, Suite 30
- Seattle, WA 98109-3542

- Constance M. Pechura, Ph.D.
- Robert Wood Johnson Foundation
- P.O. Box 231
- Route 1 and College Road East
- Princeton, NJ 08543-2316

## Observers

- Irene Stith-Coleman, Ph.D.
- Public Health Advisor
- Department of Health and Human Services
- 200 Independence Avenue, S.E., Room 701
- Washington, DC 20201

- Pat Cunningham, F.N.P.
- Family Medicine
- 1127 Union Avenue
- Memphis, TN 38104-6646

- Karen Dale
- Vice President / Product Development
- Lifescape, LLC
- 8614 Westwood Center Drive
- Suite 20
- Vienna VA 22182-2233

- Linda Gask, M.D.
- MacColl Institute for HealthCare Innovation
- 1730 Minor Avenue, Suite 129
- Seattle, WA 98101-1448

- John M. Hill
- President
- ValueOption
- 3110 Fairview Park Drive
- Falls Church, VA 22042

- Shelley Jackson, J.D.
- Senior Civil Rights Analyst
- Department of Health and Human Services
- Office of Civil Rights
- 200 Independence Avenue, S.W., Room 574E
- Washington, DC 20201

- Maria Llorente, M.D.
- Associate Professor and Chief
- Division of Geriatric Psychiatry, Department of Psychiatry and Behavioral Sciences
- University of Miami School of Medicine and Miami Veterans' Administration Medical Center
- 1201 N.W. 16th Street, #116
- Miami, FL 33125-1693

- Sue Martone
- Public Health Analyst
- Health Resources and Services Administration
- Department of Health & Human Service
- 5600 Fishers Lane
- Rockville, MD 20857

- Darlene Marion Meador, Ph.D.
- Director
- Program and Policy Development Section
- Division of Mental Health, Mental Retardation and Substance Abuse
- Georgia Department of Human Resources
- 2 Peachtree Street, N.W.
- Suite 23-41
- Atlanta, GA 30303-3171

- David Mosen, Ph.D.
- Outcomes Analyst/Research Associate
- Institute for Health Care Delivery Research
- Intermountain Health Care
- 36 South State Street, 16th Floor
- Salt Lake City, UT 84111-1633

- Joanne Nicholson, Ph.D.
- Associate Professor
- Department of Psychiatry, an
- Associate Director
- Center for Mental Health Services Research
- Homeless Families Program
- The Family Health Center
- Department of Family Medicine and Community Health
- University of Massachusetts Medical School
- 55 Lake Avenue North
- Worcester, MA 01655-0242

- CAPT Tina Russ, Ph.D.
- Health Psychology Consultant
- USA
- Office for Prevention and Health Services Assessment
- AFMOA/SGZZ 2602 Doolittle Road, Building 80
- Brooks Air Force Base, TX 78235-5249

- Pat Salomon, M.D.
- Director
- Office of Early Childhood
- Substance Abuse and Mental Health Services Administration
- 5600 Fishers Lane
- Rockville, MD 20857

- Bertha N. Williams, MS, RN
- Presidential Management Intern
- Office of Public Health and Science
- Department of Health and Human Services
- 200 Independence Avenue, S.E., Room 714
- Washington, DC 20201