# Appendix B Resource Directory

## Federal Lead Agencies

- Office of the Surgeon General (OSG)
- 5600 Fishers Lane
- Rockville, MD 20857
- Tel: 301-443-4000
- Fax: 301-443-3574
- www.surgeongeneral.gov

- Center for Mental Health Services (CMHS)
- Knowledge Exchange Network
- P.O. Box 42490
- Washington, DC 20015
- Tel: 800-789-2647
- Fax:301-984-8796
- www.mentalhealth.org

- National Institute of Mental Health (NIMH)
- Office of Communications and Public Liaison
- 6001 Executive Boulevard
- Room 8184, MSC 9663
- Bethesda, MD 20892-9663
- Tel: 301-443-4513
- TTY: 301-443-8431
- Fax: 301-443-4279
- www.nimh.nih.gov

- Substance Abuse and Mental Health Services Administration (SAMHSA)
- Office of the Administrator
- 5600 Fishers Lane, Room 12-105
- Rockville, MD 20857
- Tel: 301-443-2271
- www.samhsa.gov

## Additional Federal Resources

- Office of the Secretary
- 200 Independence Avenue, S.W.
- Washington, DC 20201
- Tel: 202-690-7000
- www.hhs.gov/agencies/os.html

- Administration for Children and Families
- 370 L'Enfant Promenade, S.W.
- Washington, DC 20447
- www.acf.dhhs.gov

- Administration on Aging
- National Aging Information Center
- 330 Independence Avenue, SW
- Washington, DC 20201
- Tel: 202-619-7501
- Tel: 800-677-1116 (Eldercare Locator)
- www.aoa.dhhs.gov

- Agency for Health Care Research and Quality
- Publications Clearinghouse
- P.O. Box 8547
- Silver Spring, MD 20907
- Tel: 800-358-9295
- www.ahcpr.gov

- Centers for Disease Control and Prevention
- 1600 Clifton Road
- Atlanta, GA 30333
- Tel: 800-311-3435 or 404-639-3534
- www.cdc.gov

- Centers for Medicare and Medicaid Services
- 500 Securities Boulevard
- Baltimore, MD 21244
- Tel: 410-786-3000
- http://cms.hhs.gov

- Food and Drug Administration
- Center for Drugs, Evaluation and Safety
- 5600 Fishers Lane, RM 12B-31
- Rockville, MD 20857
- Tel: 888-INFO-FDA (888-463-6332)
- www.fda.gov

- Health Resources and Services Administration
- Clearinghouse on Maternal and Child Health
- 2070 Chain Bridge Road, # 450
- Vienna, VA 22182
- Tel: 888-434-4mch
- www.nmchc.org

- Indian Health Service
- Headquarters East
- Parklawn Building
- 5600 Fishers Lane
- Rockville, MD 20857
- www.ihs.gov

- National Institutes of Health
- Bethesda, MD 20892
- www.nih.gov

- National Center on Minority Health and Health Disparities
- 6707 Democracy Boulevard, Suite 800
- Bethesda, MD 200892-5465
- Tel: 301-402-1366
- Fax: 301-402-7040
- http://ncmhd.nih.gov

- National Institute on Aging Alzheimer's Disease Education and Referral Center
- P.O. Box 8250
- Silver Spring, MD 20898-8057 Tel: 800-438-4380
- www.alzheimers.org

- National Institute on Alcohol Abuse and Alcoholism
- Office of Scientific Communication
- 6000 Executive Boulevard, Suite 409
- Bethesda, MD 20892-7003
- Tel: 301-443-3860
- www.niaaa.nih.gov

- National Institute on Child Health and Human Development
- NICHD Clearinghouse
- P.O. Box 3006
- Rockville, MD 20847
- Tel: 800-370-2943
- www.nichd.nih.gov

- National Institute on Drug Abuse
- 6001 Executive Boulevard, Room 5213
- Bethesda, MD 20892-1124
- www.drugabuse.gov

- National Institute on Neurological Disorders and Stroke
- Office of Communications and Public Liaison
- P.O. Box 5801
- Bethesda, MD 20824
- Tel: 301-496-5751
- www.ninds.nih.gov

- National Clearinghouse for Alcohol and Drug Information
- P.O. Box 2345
- Rockville, MD 20847-2600
- Tel: 800-729-6686 or 301-468-2600
- Fax: 301-468-6433
- TDD: 800-487-4889
- www.health.org

- National Clearinghouse on Child Abuse and Neglect Information
- P.O. BOX 1182
- Washington, DC 20013-1182
- Tel: 800-FYI-3366 or 703-385-7565
- Fax: 703-385-3206
- https://www.childwelfare.gov/can/

- National Information Center for Children and Youth with Disabilities
- P.O. Box 1492
- Washington, DC 20013
- Tel: 800-695-0285
- Fax: 202-884-8441
- www.nichcy.org/

- Office of Minority Health Resource Center U.S. Department of Health and Human Services
- P.O. Box 37337
- Washington, DC 20013-7337
- Tel: 800-444-6472
- http://minorityhealth.hhs.gov

- Rehabilitation Services Administration U.S. Department of Education
- 330 C Street, S.W. Room 3211
- Washington, DC 20202
- Tel: 202-205-5474
- www.ed.gov/offices/OSERS/RSA

- Rural Information Center Health Service
- (A joint project of the U.S. Department of Health and Human Services and U.S. Department of Agriculture)
- National Agricultural Library, Room 304
- 10301 Baltimore Avenue
- Beltsville, MD 20705-2351
- Tel: 301-504-5755 or 800-633-7701
- www.nal.usda.gov/ric/richs

- Substance Abuse and Mental Health Services Administration

- Center for Substance Abuse Prevention
- www.samhsa.gov/csap

- Center for Substance Abuse Treatment
- www.samhsa.gov/centers/csat/csat.html

- Office of Minority Health
- Rockville, MD 20857
- 5600 Fishers Lane, Room 10-75
- Tel: 301-443-7265

- Refugee Mental Health Program
- www.samhsa.gov/centers/cmhs/cmhs.html
- Special Populations, Refugee Mental Health

- Veterans Health Administration
- 1120 Vermont Avenue, NW
- Washington, DC 20421
- Tel: 800-827-1000
- www.va.gov/vbs/health/index.htm

## General Federal Government Web Sites

- Consumer Information Center
- www.pueblo.gsa.gov

- Health Finder
- www.healthfinder.gov

- The Center for Mental Health Services (KEN)
- www.mentalhealth.org

- National Library of Medicine
- www.nlm.nih.gov

- National Women's Health Information Center
- www.4woman.gov

- Substance Abuse and Mental Health Services Administration
- www.samhsa.gov

- U.S. Consumer Gateway-Health
- www.consumer.gov/health

## Resources for Specific Racial and Ethnic Groups

### African Americans

- African American Mental Health Research Center
- Institute for Social Research
- University of Michigan
- 426 Thompson, Room 5518
- Ann Arbor, MI 48106
- www.isr.umich.edu/rcgd/prba/index.html

- Association of Black Psychologists
- P.O. Box 55999
- Washington, DC 20040-5999
- Tel: 202-722-0808
- www.abpsi.org

- Black Health Network
- www.blackhealthnetwork.com

- Black Psychiatrists of America
- 866 Carlson Avenue
- Oakland, CA 94610
- Tel: 510-834-7103
- Fax: 510-695-9830

- Minority Health Professions Foundation
- 3 Executive Park Drive, NE, Suite 100
- Atlanta, GA 30329
- Tel: 404-634-1993
- www.minorityhealth.org

- National Association for the Advancement
- of Colored People National Health Coordinator
- 4805 Mt. Hope Drive
- Baltimore, MD 21215
- Tel: 410-486-9147
- www.naacp.org

- National Association of Black Social Workers
- 8436 West McNichols Street
- Detroit, MI 48221
- Tel: 313-862-6700
- http://ssw.unc.edu/professional/NABSW.html

- National Black Child Development Institute
- 1023 15th Street, NW, Suite 600
- Washington, DC 20005
- Tel: 202-387-1281 or 800-556-2234
- www.nbcdi.org

- National Medical Association
- 1012 Tenth Street, NW
- Washington, DC 20001
- Tel: 202-347-1895
- www.nmanet.org

### American Indians and Alaska Natives

- Association of American Indian Physicians
- 1225 Sovereign Row, Suite 103
- Oklahoma City, OK 73108
- Tel: 405-946-7072
- Fax:405-946-7651
- www.aaip.com

- Indian Health Service
- 5600 Fishers Lane
- Parklawn Building, Room 6-35
- Rockville, MD 20857
- Tel: 301-443-3593
- www.ihs.gov

- National Center for American Indian and Alaska Native Mental Health Research
- University of Colorado Health Sciences Center
- Department of Psychiatry, North Pavilion
- 4455 East 12th Avenue, Campus Box A011-13
- Denver, CO 80220
- Tel: 303-315-9232
- www.uchsc.edu/sm/ncaianmhr

- National Congress of American Indians
- 1301 Connecticut Avenue NW
- Suite 200
- Washington DC 20036 202-466-7767
- fax: 202-466-7797
- www.ncai.org

- National Indian Child Welfare Association
- 5100 S Macadam Avenue, Suite 300
- Portland, OR 97201
- Tel: 503-222-4044
- Fax:503-222-4007
- www.nicwa.org

- National Indian Health Board
- Nez Perce Tribal Council
- 1385 South Colorado Boulevard, Suite A-707
- Denver, CA 80222
- Tel: 303-759-3075
- www.nihb.org

- National Native American AIDS Prevention Center
- 436 14th Street, Suite 1020
- Oakland, CA 94612
- Tel: 510-444-2051
- www.nnaapc.org

- Native Elder Health Care Resource Center
- University of Colorado
- Department of Psychiatry
- 4455 East 12th Avenue, Campus Box A011-13
- Denver, CO 80220
- Tel: 303-315-9351
- www.uchsc.edu/sm/nehcrc

- Society of Indian Psychologists
- Oklahoma State University
- 215 N. Murray Hall
- Stillwater, OK 74078
- 405-744-6027
- jchaney@okstate.edu

### Asian Americans and Pacific Islanders

- Asian American Psychological Association
- 3003 North Central Avenue, Suite 103-198
- Phoenix, AZ 85012
- Tel: 602-230-4257
- www.west.asu.edu/aapa

- Asian and Pacific Islander American Health Forum
- 942 Market Street, Suite 200
- San Francisco, CA 94102
- Tel: 415-954-9988
- Washington, DC area: 703-841-9128
- www.apiahf.org

- Association of Asian Pacific Community Health Organizations
- 439 23rd Street
- Oakland, CA 94612
- Tel: 510-272-9536
- www.aapcho.org

- National Asian Pacific American Families Against Substance Abuse
- 340 East Second Street, Suite 409
- Los Angeles, CA 90012
- Tel: 213-625-5795
- www.napafasa.org

- National Asian Women's Health Organization
- 250 Montgomery Street, Suite 900
- San Francisco, CA 94104
- Tel: 415-989-9747
- Fax: 415-989-9758
- www.nawho.org

- National Research Center on Asian American Mental Health
- Department of Psychology
- University of California
- One Shields Avenue
- Davis, CA 95616-8686
- Tel: 530-752-1400
- nrcaamh.ucdavis.edu

- Refugee Health Issues Center
- American Refugee Committee
- 430 Oakgrove Street, Suite 204
- Minneapolis, MN 55404
- Tel: 612-872-7060
- www.archq.org

- South Asian Women's NETwork (Sawnet)
- www.umiacs.umd.edu/users/sawweb/sawnet/health.html
- Or www.api-healthline.net

### Hispanics/Latinos

- Association of Hispanic Mental Health Professionals
- P.O. Box 7631, F.D.R. Station
- New York, NY 10150-1913
- Tel: 718-960-0208
- www.hispanicfederation.org/agencies/ahmhp.htm

- Centros Para el Control y la Prevencion de Enfermedades
- (CDC Spanish Language Web Site)
- 1600 Clifton Road
- Atlanta, GA 30333
- Tel: 800-311-3435
- www.cdc.gov/spanish

- Latino Research Program Project (LRPP)
- Center for Evaluation and Sociomedical Research
- Medical Sciences Campus
- Main Building 3rd Floor
- GPO BOX 365067
- San Juan, P.R. 00936-5067
- Telephone (787) 758-2525 extensions 1422, 1423
- http://latino.rcm.upr.edu/index.html

- National Alliance for Hispanic Health
- (formerly COSSMHO)
- 1501 16th Street, NW
- Washington, DC 20036-1401
- Tel: 202-387-5000
- www.hispanichealth.org

- National Hispanic Medical Association
- 1700 17th Street, NW, Suite 405
- Washington, DC 20009
- Tel: 202-265-4297
- home.earthlink.net/~nhma

- National Latina Health Network
- 1680 Wisconsin Avenue, NW, 2nd Floor
- Washington, DC 20007
- Tel: 202-965-9633
- NLHN@erols.com

- National Latina Health Organization
- P.O. Box 7567
- Oakland, CA 94601
- Tel: 510-534-1362
- Fax:510-534-1364
- clnet.ucr.edu/women/nlho

- National Latino Behavioral Health Association
- www.nlbha.org

- UCLA LatinoMentalHealth.net
- www.latinomentalhealth.net

### Multicultural

- Association for Multicultural Counseling and Development
- 5999 Stevenson Avenue
- Alexandria, VA 22304
- Tel: 703-823-9800 or 800-347-6647
- www.counseling.org

- The Center for Multicultural and Multilingual Mental Health Services
- 4750 N. Sheridan Road
- Suite 300
- Chicago, IL 60640
- Tel: 312-271-1073
- www.mc-mlmhs.org

- DiversityRx
- www.diversityRx.org

- National Center for Cultural Competence
- Georgetown University
- Child Development Center
- 3307 M Street, NW, Suite 401
- Washington, DC 20007-3935
- Toll free: 800-788-2066
- Tel: 202-687-5387
- Fax: 202-687-8899
- www.gucdc.georgetown.edu/nccc/

- National Minority AIDS Council
- 1931 13th Street, NW
- Washington, DC 20009-4432
- Tel: 202-483-6622
- Fax:202-483-1135
- www.nmac.org

- Research Center on the Psychobiology of Ethnicity
- UCLA Medical Center
- Department of Psychiatry
- 1000 West Carson Street
- Torrance, CA 90509
- Tel: 213-533-3188
- www.rei.edu/centers/Ethnicity_Center.htm

- Search Institute
- 700 South Third Street, Suite 210
- Minneapolis, MN 55415
- Tel: 612-376-8955
- Toll Free: 1-800-888-7828
- Fax: 512-376-8956
- www.search-institute.org

- The Society for the Psychological Study of Ethnic Minority Issues
- Division 45 of the American Psychological Association
- www.apa.org/divisions/div45

- Transcultural & Multicultural Health Links
- www.iun.edu/~libemb/trannurs/trannurs.htm