# Appendix A Inclusion of Minorities in Controlled Clinical Trials Used to Develop Professional Treatment Guidelines for Major Mental Disorders

This appendix^1^ examined the inclusion of racial and ethnic minorities in randomized clinical trials used to develop professional guidelines for treatment of four specific mental disorders: bipolar disorder, major depression, schizophrenia, and attention-deficit/hyperactivity disorder.

1 This Appendix was prepared by the Senior Scientific Editor for this Supplement

The American Psychiatric Association (1994) developed practice guidelines for treatment of patients with bipolar disorder. Their guidelines were based on a review of all relevant studies, including randomized con-trolled clinical trials. This appendix considered the representation of minorities in all randomized trials conducted in the United States during the most recent 10-year period (1983-1994). Results are presented in Table A-1. Seventeen of these studies represented 16 separate patient populations. Two articles reported on the same subjects, but these subjects are only included once in this review. Of 825 participants, 29 were identified as non-white, and 32 were identified as black. No analyses were conducted to determine if these participants differed from white participants in outcomes. As a result, the treatment guidelines for patients with bipolar disorder developed by the APA do not offer any information on expected outcomes for minority persons.

The American Psychiatric Association (1997) conducted a similar review to develop guidelines for schizophrenia. Results are presented in Table A-2. Twenty-five randomized clinical trials that occurred in the United States between 1986 and 1997 were included in this analysis. A total of 2,865 participants were included in these 25 studies. Of those participants, 316 were identified as nonwhite, 376 as African American, 40 as Hispanic, and 3 as Asian American. Although several studies had a modest African American sample (39-74), none analyzed results separately for African Americans or presented outcomes specifically for them. As a result, the guidelines developed by the APA to guide treatments for those with schizophrenia do not provide information regarding potentially different outcomes for African Americans or any other ethnic minorities.

The American Psychiatric Association (2000) conducted a similar review to develop treatment guidelines for major depression. Randomized clinical trials conducted between 1986-1997 were evaluated, with 27 studies included. Results are presented in Table A-3. A total of 3,980 patients were involved. Amoung them, 241 were nonwhite, 150 were African American, and 2 were Asian American. None of the studies analyzed minority participants separately. The one study with a sizeable African American population (N=123) did find similar clinical outcomes as a result of depression care, although there were differences in functional outcomes.

To examine the inclusion of ethnic minority children in research, this appendix reviewed the randomized trials of interventions for attention-deficit/hyperactivity disorder (AD/HD) used by a multidisciplinary team assembled by the Agency for Healthcare Research and Quality (AHRQ). These trials were used to develop an evidence-based report on treatment (AHRQ, 1999). Thirty-two studies from 1988 to 1999 were eligible for review. Results are presented in Table 4. These studies evaluated 1,657 children with AD/HD. Of those children, 126 were African American, 55 Hispanic, 4 nonwhite, and 1 each Asian American, Pacific Islander, East Indian, and Asian Indian. With the exception of the recent multisite study sponsored by the National Institute of Mental Health, the largest inclusion of minorities in any study was 5. However, in the recent NIMH trial, 115 African Americans and 48 Latinos were included. Although not analyzed separately in this Supplement, further reports analyzing outcomes for the ethnic minorities could still be forthcoming.

The American Psychological Association recently reviewed empirically validated therapies, namely, those therapies judged by a panel of scientists to be effective, according to explicit criteria for empirical studies (Chambless et al., 1996). Their report states: Examining the citations for empirically validated therapies identified in the 1995 task force report, we find not a single study included tests of the efficacy of the treatment for ethnic minority populations. Most investigators did not specify ethnicity of subjects or used only white subects. Out of about 41 studies cited, only 6-7 made any reference to race or ethnicity of subjects. No one used ethnicity as a variable of interest.

Overall, minorities are not represented in studies that evaluate the impact of interventions for major mental disorders. Furthermore, when minorities are included, rarely are analyses conducted to determine whether the treatments are as effective for them as they are for white populations. Although a great deal is known about efficacy of a wide range of interventions for treating common mental disorders, specific information about the efficacy of these interventions for racial and ethnic minority populations is unavailable.

## References

Agency for Healthcare Research and Quality (1999). Treatment of Attention-Deficit/Hyperactivity Disorder: Summary, evidence report/technology assessment No. 11 (AHCPR Publication No. 99-E018), Rockville,, MD:. Author
American Psychiatric Association. ((1994).). Practice guideline for treatment of patients with bipolar disorder. American Journal of Psychiatry,.
American Psychiatric Association. ((1997).). Practice guideline for treatment of patients with bipolar disorder. American Journal of Psychiatry,.
American Psychiatric Association. ((2000).). Practice guideline for treatment of patients with bipolar disorder. American Journal of Psychiatry,.
Chambless, D. L., Sanderson, W. C., Shoham, V., Bennett Johnson, S., Pope, K. S., Crits-Christoph, P., Baker, M., Johnson, B., Woody, S. R., Sue, S., Beutler, L., Williams, D. A., & McCurry, S (1996). An update on empirically validated therapies The Clinical Psychologist, 49, 5 18

## Table A-1: Representation of Minorities in Randomized Controlled Trials for Treatment of Bipolar Disorder

Table A-1: Representation of Minorities in Randomized Controlled Trials for Treatment of Bipolar Disorder.

Table A-1: Representation of Minorities in Randomized Controlled Trials for Treatment of Bipolar Disorder

Study | Sample | Information on ethnicity of sample | Analyses by ethnicity
Dubovsky, Franks, Allen, & Murphy, (1986) | N = 7 | No | No
Giannini, Taraszewski, & Loiselle, (1987) | N = 20 | All white, male patients | N/A
Cohn, Collins, Ashbrook, et al., (1989) | N = 89 | No | No
Gelenberg, Kane, Keller, et al., (1989) | N = 94 | No mention | No
Clarkin, Glick, Haas, et al., (1990) | N = 50 | 35 white 15 nonwhite | No
Gallagher-Thompson, Hanley-Peterson, & Thompson, (1990) | N = 91 | No | No
O'Leary & Beach, (1990) | N = 36 couples | No | No
Himmelhoch, Thase, Mallinger, et al., (1991) | N = 56 | 52 white 4 nonwhite | No
Jacobson, Dobson, Fruzzetti, et al., (1991) | N = 60 couples | No | No
Pope, McElroy, Keck, et al., (1991) | N = 36 | No | No
Small, Klapper, Milstein, et al., (1991) | N = 52 | No | No
Garza-Treviño, Overall, & Hollister, (1992) | N = 20 | No | No
Lenox, Newhouse, & Creelman, (1992) | N = 20 | No | No
Bowden, Brugger, Swann, et al., (1994) | N = 179 | 127 white 32 black 20 other | No
Sachs, Lafer, Stoll, et al., (1994) | N = 15 | No | No

Table excludes studies published before 1986.

Table excludes studies with samples outside United States.

### References

Bowden, C. L., Brugger, A. M., Swann, A. C., Calabrese, J. R., Janicak, P 6., Petty, F., Dilsaver, S.C., Davis, J. M., Rush, A. J., Small, J. 6., Garza-Treviño, E. S., Risch, S. C., Goodnick, P. J., & Morris, D. D. ((1994)). Efficacy of divalproex vs lithium and placebo in the treatment of mania. The Depakote Mania Study Group. Journal of the American Medical Association.
Clarkin, J. F., Glick, I. D., Hass, G. L., Spencer, J. H., Lewis, A. B., Peyser, J., DeMane, N., Good-Ellis, M., Harris, E., & Lestelle, V. ((1990)). A randomized clinical trial of inpatient family intervention. V. Results for affective disorders. Journal of Affective Disorders,.
Cohn, J. B., Collins, 6., Ashbrook, E., & Wernicke, J. F. ((1989)). A comparison of fluoxetine imipramine and placebo in patients with bipolar depressive disorder. International ClinicalPsychopharmacology,.
Dubovsky, S. L., Franks, R. D., Allen, S., & Murphy, J. ((1986)). Calcium antagonists in mania: A double-blind study of verapolmil. Psychiatry Research,.
Gallagher-Thompson,D., Hanley-Peterson, P.,& Thompson, L. W. ((1990)). Maintenance of gains versus relapse following brief psychotherapy for depression. Journal of Consulting Clinical Psychology,.
Garza-Treviño, E. S., Overall, J. E., & Hollister, L. E. ((1992)). Verapamil versus lithium in acute mania. American Journal of Psychiatry,.
Gelenberg, A. J., Kane, J. M., Keller, M. B., Lavori, P., Rosenbaum, J. F., Cole, K., & Lavelle, J. ((1989)). Comparison of standard and low serum levels of lithium for maintenance treatment of bipolar disorder. New England Journal of Medicine,.
Giannini, A. J., Taraszewski, R., & Loiselle, R. H. ((1987)). Verapamil and lithium in maintenance therapy of manic patients. Journal of Clinical Pharmacology,.
Himmelhoch, J. M., Thase, M. E., Mallinger, A. G., & Houck, P. ((1991)). Tranylcypromine versus imipramine in anergic bipolar depression. American Journal of Psychiatry,.
Jacobson, N. S., Dobson, K., Fruzzettii, A. E., Schmaling, K. B., & Salusky, 5. ((1991)). Marital therapy as a treatment for depression. Journal of Consulting Clinical Psychology,.
Lenox, R. H., Newhouse, P. A., Creelman, W. L., & Whitaker, T. M. ((1992)). Adjunctive treatment of manic agitation with lorazepam versus haloperidol: A double-blind study. Journal of Clinical Psychiatry,.
O'Leary, K. D., Beach, S. R. ((1990)). Marital Therapy: A viable treatment for depression and marital discord. American Journal of Psychiatry,.
Pope, H. G., Jr., McElroy, S. L., Keck, P. E., Jr., & Hudson, J. I. ((1991)). Valproate in the treatment of acute mania: A placebo controlled study. Archives of General Psychiatry.
Sachs, G. S., Lafer, B., Stoll, A. L., Banov, M., Thibault, A. B., Tohen, M., & Rosenbaum, J. E. ((1994)). A double-blind trial of bupropion versus desipramine for bipolar depression. Journal of Clinical Psychiatry,.
((1991).). Carbamazepine compared with lithium in the treatment of mania. Archives of General Psychiatry,.

## Table A-2: Representation of Minorities in Randomized Controlled Trials for Treatment of Schizophrenia

Table A-2: Representation of Minorities in Randomized Controlled Trials for Treatment of Schizophrenia.

Table A-2: Representation of Minorities in Randomized Controlled Trials for Treatment of Schizophrenia

Study | Sample | Information on ethnicity of sample | Analyses by ethnicity
Hogarty, Anderson, Reiss, et al., (1986) | N = 103 | 81% white (n = 83.4) No other information | No
Carpenter, Heinrichs, & Hanlon, (1987) | N = 42 | 8 white 34 black | No
Claghorn, Honigfeld, & Abuzzahab, (1987) | N = 151 | No | No
Marder, Van Putten, Mintz, et al., (1987) | N = 66 | 32% white (n = 21) 59% black (n = 39) 6% Hispanic (n = 4) 3% other (n = 2) | No
Csernansky, Riney, Lombrozo, et al., (1988) | N = 55 | No | No
Hogarty, McEvoy, Munetz, et al., (1988) | N = 70 | 67% white (n = 47) No other information | No
Kane, Honigfeld, Singer, et al., (1988) | N = 319 | 65% white (n = 208) 23% black (n = 74) 10% Hispanic (n = 31) 1% Asian (n = 2) 1% other (n = 4) | No
Kramer, Vogel, DiJohnson, et al., (1989) | N = 58 | No | No
Herz, Glazer, Mostert, et al., (1991) | N = 101 | 56 white 45 black | No
Salzman, Solomon, Miyawaki, et al., (1991) | N = 60 | No | No
Borison, Pathiraja, Diamond, et al., (1992) | N = 36 | 20 white 15 black 1 Hispanic | No
Eckman, Wirshing, Marder, et al., (1992) | N = 41 (40 with ethnic data available) | 14 white 23 black 3 Hispanic | No
Pickar, Owen, Litman, et al., (1992) | N = 21 | No | No
Breier, Buchanan, Irish, et al., (1993) | N = 35 | 26 white 9 black | No
McEvoy, Borrison, Small, et al., (1993) | N = 38 | No | No
Marder & Meibach, (1994) | N = 388 | 244 white 144 nonwhite | No
Marder, Wirshing, Van Putten, et al., (1994) | N = 80 | 58 nonwhite No other information | No
Randolph, Eth Glynn, et al., (1994) | N = 41 | 14 white 19 black, 5 Hispanic 3 Asian | No
DeSisto, Harding, McCormick, et al., (1995) | N = 269 | No | No
Hogarty, McEvoy, Ulrich, et al., (1995) | N = 128 (trial 1), same pool of subjects used for 2 subsequent trials | Trial 1: 74% white (n = 95) Trial 2: no information Trial 3: 83% white (n = 51) | No
Beasley, Tollefson, Tran, et al., (1996) | N = 335 (299 subjects with race reported) | *77% white (n = 230) 23% black (n = 69) | No
Drake, McHugo, Becker, et al., (1996) | N = 143 | 95% white (n = 136) No other information | No
Marder, Wirshing, Mintz, et al., (1996) (different study from Marder 1994 above) | N = 80 | No | No
Schulz, Mack, Zborowski, et al., (1996) | No sample size reported (brief report of findings from "two large" studies) | No | No
van Kammen, McEvoy, Targum, et al., (1996) | N = 153 in evaluable data set with demographic information reported (205 randomized) | 59% white (n = 90) 32% black (n = 49) 9% other (n = 14) | No

* information is approximate (numbers in published table do not add up to total sample size).

Table excludes studies published before 1986.

Table excludes studies with samples outside United States.

### References

Beasley, C. M., Jr., Tollefson, G., Tran, P., Satterlee, W., Sanger, T., Hamilton, S., Fabre, L., Small, J., Ereshevsky, L., True, J., Nemeroff, C., Risch, S. C., Perry, P. J., Potkin, S. 6., Borison, R. L., James, S., Meltzewr, H. Y., Ighal, N., Fann, W. E., Gewitt, 6. R., Landbloom, R., Roybyme, P. P, Tudson, V. B., Carman, I. S., Stokes, P. E., et al. ((1996)). Olanzapine versus placebo and haloperidol: Acute phase results of the North American double-blind olanzapine trial. Neuropsychopharmacology,.
Borison, R. L., Pathiraja, A. P., Diamond, B. I., & Meibach, R. C. ((1992)). Risperidone: Clinical safety and efficacy in schizophrenia. Psychopharmacological Bulletin,.
Breier, A., Buchanan, R. W., Irish, D., & Carpenter, W T., Jr. ((1993)). Clozapine treatment of outpatients with schizophrenia: Outcome and long-term response patterns. Hospital and Community Psychiatry,.
Carpenter, W. T., Jr., Heinrichs, D. W., & Hanlon, T. E. ((1987)). A comparative trial of pharmacologic strategies in schizophrenia. American Journal of Psychiatry,.
Claghorn, J., Honigfeld, 6., Abuzzahab, F. S., Wang, R., Steinbook, R., Tuason, V., & Klerman, 6. ((1987)). The risks and benefits of clozapine versus chlorpromazine. Journal of Clinical Psychopharmacology,.
Csernansky, J. 6., Riney, S. J., Lombarozo, L., Overall, J. E., & Hollister, L. E. ((1988)). Double-blind comparison of alprazolam, diazepam and placebo for the treatment of negative schizophrenic symptoms. Archives of General Psychiatry,.
De Sisto, M. J., Harding, C. M., McCormick, R. V., Ashikaga, T., & Brooks, G. W. ((1995)). The Maine and Vermont three-decade studies of serious mental illness, I: Matched comparison of cross-sectional outcome. British Journal of Psychiatry,.
Drake, R. E., McHugo, 6. J., Becker, D. R., Anthony, W. A., & Clark, R. E. ((1996)). The New Hampshire study of supported employment for people with severe mental illness. Journal of Consulting Clinical Psychology,.
Eckman, T. A., Wirshing, W. C., Marder, S. R., Liberman, R. P, Johnston-Cronk, K., Zimmermann, K., & Mintz, J. ((1992)). Technique for training schizophrenic patients in illness self-management: A controlled trial. American Journal of Psychiatry,.
Herz, M. I., Glazer, W M., Mostert, M. A., Sheard, M. A., Szymanski, H. V., Hafez, H., Mirza, M., & Vana, J. ((1991)). Intermittent vs. maintenance medication in schizophrenia: Two-year results. Archives of General Psychiatry,.
Hogarty, G.E., Anderson, C. M., Reiss, D. J., Komblith, S. J., Greenwald, D. P, Javna, C. D., & Madonia, M. I. ((1986)). Family psychoeducation, social skills training, and maintenance chemotherapy in the aftercare treatment of schizophrenia, I: One-year effects of a controlled study on relapse and expressed emotion. Archives of General Psychiatry,.
Hogarty, G.E., McEvoy, J. P, Munetz, M., DiBarry, A. L., Bartone, P, Cather, R., Cooley, S. J., Ulneb, R. E, Carter, M., & Madonia, M. J. (Environmentallpersonal Indicators in the Course of Schizophrenia Research Group). ((1988)). Dose of fluphenazine, familial expressed emotion, and outcome in schizophrenia: Results of a two-year controlled study. Archives of General Psychiatry,.
Hogarty, G.E., McEvoy, J. P, Ulrich, R. E, DiBarry, A. L., Bartone, P., Cooley, S., Hammill, K., Carter, M., Munetz, M. R., & Perel, J. ((1995)). Pharmacotherapy of impaired affect in recovering schizophrenic patients. Archives of General Psychiatry,.
Kane, J., Honigfeld, G., Singer, J., & Meltzer, H. ((1988)). Clozapine for the treatment-resistant schizophrenic: A double-blind comparison with chlorpromazine. Archives of General Psychiatry,.
Kramer, M. S., Vogel, W. H., DiJohnson, C., Dewey, D. A., Sheves, P, Cavicchia, S., Little, P, Schmidt, R., & Kimes, I. ((1989)). Antidepressants in "depressed" schizophrenic inpatients: A controlled trial. Archives of General Psychiatry,.
Marder, S. R., & Meibach, R. C. ((1994)). Risperidone in the treatment of schizophrenia. American Journal of Psychiatry,.
Marder, S. R., Van Putten, T., Mintz, J., Lebell, M., McKenzie, J., & May, P R. ((1987)). Low- and conventional-dose maintenance therapy with fluphenazine decanoate: Two-year outcome. Archives of General Psychiatry,.
Marder, S. R., Wirshing, W. C., Mintz, J., McKenzie, J., Johnston, K., Eckman, T. A., Lebell, M., Zimmerman, K., & Liberman, R. P. ((1996)). Two-year outcome of social skills training and group psychotherapy for out-patients with schizophrenia. American Journal of Psychiatry,.
Marder, S. R., Wirshing, W. C., Van Putten, T., Mintz, J., McKenzie, J., Johnston-Cronk, K., Lebell, M., & Liberman, R. P. ((1994)). Fluphenazine vs placebo supplementation for prodromal signs of relapse in schizophrenia. Archives of General Psychiatry.
McEvoy, J., Borison, R., Small, J., van Kammen, D., Meltzer, H., Hamner, M., Morris, D., Shu, V., Sebree, T., & Grebb, J. ((1993)). The efficacy and tolerability of sertindole in schizophrenic patients: A pilot double-blind placebo controlled, dose ranging study. Schizophrenia Research,.
Pickar, D., Owen, R. R., Litman, R. E., Konicki, E., Gutierrez, R., & Rapaport, M. H. ((1992)). Clinical and biologic response to clozapine in patients with schizophrenia: Crossover comparison with fluphenazine. Archives of General Psychiatry,.
Randolph, E. T., Eth, S., Glynn, S. M., Paz, G. G., Leong, G. B., Shaner, A. L., Strachan, A., Van Vort, W., Escobar, J. I., & Liberman, R. P. ((1994)). Behavioural family management in schizophrenia: Outcome of a clinic-based intervention. British Journal of Psychiatry,.
Salzman, C., Solomon, D., Miyawaki, E., Glassman, R., Rood, L., Flowers, E., & Thayer, 5. ((1991)). Parenteral lorazepam versus parenteral haloperidol for the control of psychotic disruptive behavior. Journal of Clinical Psychiatry,.
van Kammen, D. P., McEvoy, J. P., Targum, S. D., Kardatzke, D., & Sebree, T. B. ((1996)). A randomized controlled dose-ranging trial of sertindole in patients withschizophrenia. Psychopharmacology,.

## Table A-3: Representation of Minorities in Randomized Controlled Trials for Treatment of Depression

Table A-3: Representation of Minorities in Randomized Controlled Trials for Treatment of Depression.

Table A-3: Representation of Minorities in Randomized Controlled Trials for Treatment of Depression

Study | Sample | Information on ethnicity of sample | Analyses by ethnicity
Kocsis, Frances, Voss, et al., (1988) | N = 76 | No | No
Liebowitz, Quitkin, Stewart, et al., (1988) | N = 119 | No (subject description published in 1984 report) | No
Quitkin, Stewart, McGrath, et al., (1988) | N = 60 | No | No
Elkin, Shea, Watkins, et al., (1989) | N = 239 | 212 white No other information | No
Feighner, Pambakian, Fowler, et al., (1989) | N = 45 | No | No
Frank, Kupfer, Perel, et al., (1990) | N = 128 | No | No
Quitkin, McGrath, Stewart, et al., (1990) | N = 90 (different sample from 1988 study) | No | No
Feighner, Gardner, Johnston, et al., (1991) | N = 123 | No | No
Quitkin, Harrison, Stewart, et al., (1991) | N = 64 | No | No
Kupfer, Frank, Perel, et al., (1992) | N = 20 (sample drawn from Frank, 1990) | No | No
Shea, Elkin, Imber, et al., (1992) | N = 239 (same sample as Elkin, et al., 1989) | No (1989 sample is 212/239 white, no other information) | No
Thase, Mallinger, McKnight, et al., (1992) | N = 16 | No | No
Frank, Kupfer, Perel, et al., (1993) | N = 20 (sample drawn from Frank, et al., 1990) | No | No
Sackheim, Prudic, Devanand, et al., (1993) | N = 96 | No | No
Cunningham, Borison, Carman, et al., (1994) | N = 225 | No | No
Fontaine, Ontiveros, Elie, et al., (1994) | N = 180 | No | No
Schweizer, Feighner, Mandos, et al., (1994) | N = 224 | No | No
Weisler, Johnston, Lineberry, et al., (1994) | N = 124 | 112 white No other information | No
Claghorn & Lesem, (1995) | N = 90 | No | No
McElhiney, Moody, Steif, et al., (1995) (investigates post-ECT amnesia) | N = 91 | No | No
Mendels, Reimherr, Marcus, et al., (1995) | N = 240 | 214 white 26 other | No
Kelsey, (1996) | Study 1: N = 60 Study 2: N = 312 | Study 1: No Study 2: No | Study 1: No Study 2: No
Pande, Birkett, & Fechner-Bates, (1996) | N = 42 | 38 white 2 African 2 Asian | No
Schulberg, Block, Madonia, et al., (1996) | N = 276 | 153 white No other information | No (study notes significantly more attrition among non-whites in nortriptyline condition)
Chaudhry, Najam, & Naqvi, (1998) | N = 100 | No | No
Keller, Gelenberg, Hirschfeld, et al., (1998) | N = 635 | 577 white 25 black 33 other | No
Bright, Baker, & Neimeyer, (1999) | N = 98 | 91 white (93%) No other information | No
Reynolds, Frank, Perel, et al., (1999) | N = 187 | 174 white (93.1%) No other information | No

Table excludes studies published before 1986.

Table excludes studies with samples outside United States.

### References

Bright, J. I., Baker, K. D., & Neimeyer, R. A. ((1999)). Professional and paraprofessional group treatments for depression: A comparison of cognitive-behavioral and mutual support interventions. Journal of Consulting Clinical Psychology,.
Chaudhry, J. R., Najam, N., & Naqvi, A. ((1998)). The value of amineptine in depressed patients treated with cognitive behavioural psychotherapy. Human Psychopharmacology,.
Claghorn, J. L., & Lesem, M. D. ((1995)). A double-blind placebo-controlled study of Org 3770 in depressed out-patients. Journal of Affective Disorders,.
Cunningham, L. A., Borison, R. L., Carman, J. S., Chouinard, G., Crowder, J. E, Diamond, B. I., Fishcer, D. E., & Hearst, E. ((1994)). A comparison of venlafaxine, trazodone, and placebo in major depression. Journal of Clinical Psychopharmacology,.
Elkin, I., Shea, M. T., Watkins, J. T., Imber, S.D., Sotsky, S. M., Collins, J. F., Glass, D. R., Pilkonis, P. A., Leber, W. R., Docherty, J. P., Fiester, S. J., & Parloff, M. B. ((1989)). National Institute of Mental Health Treatment of Depression Collaborative Research Program: General effectiveness of treatments. Archives of General Psychiatry,.
Feighner, J. P., Gardner, E. A., Johnson, J. A., Boltey, S. R., Khayrallah, M. A., Ascher, J. A., & Lineberry, C. G. ((1991)). Double-blind comparison of bupropion and fluoxetine in depressed outpatients. Journal of Clinical Psychiatry,.
Feighner, J. P., Pambakian, R., Fowler, R. C., Boyer, W. F, & D'Amico, M. F. ((1989)). A comparison of nefazodone, imipramine, and placebo in patients with moderate to severe depression. Psychopharmacology Bulletin,.
Fontaine, R., Ontiveros, A., Elie, R., Kensler, T. T., Roberts, D. L., Kaplita, S., Ecker, J. A., Faludi, G., & Louis, H. ((1994)). A double-blind comparison of nefazodone, imipramine, and placebo in major depression. Journal of Clinical Psychiatry,.
Frank, F., Kupfer, D. J., Perel, J. M., Cornes, C., & Mallinger, A. G. ((1990)). Three-year outcomes for maintenance therapies in recurrent depression. Archives of General Psychiatry,.
Frank, E., Kupfer, D. J., Perel, J. M., et al. ((1993)). Comparison of full dose versus half dose pharmacotherapy in the maintenance treatment of recurrent depression. Journal ofAffective Disorders,.
Keller, M. D., Gelenberg, A. J., Hirschfeld, R. M., Rush, A. J., Thase, M. E., Kocsis, J. H., Markowitz, J. C., Fawcett, J. A., Koran, L. M., Klein, D. N., Russell, J. M., Kortistein, S. G., McCullough, J. P., Davis, S. M., & Harrison, W. M. ((1998)). The treatment of chronic depression, part 2: A double-blind, randomized trial of sertraline and imipramine. Journal of Clinical Psychiatry,.
Kelsey, J. E. ((1996)). Dose-response relationship with venlafaxine. Journal of Clinical Psychopharmacology,.
Kocsis, J. H., Frances, A. J., Voss, C. B., Mann, J. J., Mason, B. J., & Sweeney, J. ((1988)). Imipramine treatment for chronic depression. Archives of General Psychiatry,.
Liebowitz, M. R., Quitkin, F M., Stewart, J. W., McGrath, P J., Harrison, W. M., Markowitz, J. S., Rabkin, J. G., Tricamo, F., Goetz, D. M., & Klein, D. G. ((1988)). Antidepressant specificity in atypical depression. Archives of General Psychiatry,.
McElhiney, M. C., Moody, B. J., Steif, B. L., Prudic, J., Devanand, D. P., Nobler, M. S., & Sackeim, H. A. ((1995)). Autobiographical memory and mood: Effects of electroconvulsive therapy. Neuropsychology.
Mendels, J., Reimherr, F., Marcus, R. N., Roberts, D. L., Francis, R. J., & Anton, S. E. ((1995)). A double-blind, placebo-controlled trial of two dose ranges of nefazodone in the treatment of depressed outpatients. Journal of Clinical Psychiatry,.
Pande, A. C., Birkett, M., Fechner-Bates, S., Haskett, R. F., & Greden, J. F. ((1996)). Fluoxetine versus phenelzine in atypical depression. Biological Psychiatry,.
Quitkin, F.M., Harrison, W., Stewart, J. W., McGrath, P J., Tricamo, F., Ocepek-Welikson, K., Rabkin, J. G., Wager, S. G., Nunes, F., & Klein, D. F. ((1991)). Response to phenelzine and imipramine in placebo non-responders with atypical depression: A new application of the crossover design. Archives of General Psychiatry,.
Quitkin, F.M., MeGrath, P. J., Stewart, J. W., Harrison, W., Tricamo, E., Wager, S. G., Ocepek-Welikson, K., Nunes, E., Rabkin, J. G., & Klein, D. F. ((1990)). Atypical depression, panic attacks, and response to imipramine and phenelzine. A replication. Archives of General Psychiatry,.
Quitkin, F.M., Stewart, J. W., McGrath, P. J., Liebowitz, M. R., Harrison, W. J., Tricamo, E., Klein, D. F., Rabkin, J. G., Markowitz, J. S., & Wager, S. G. ((1988)). Phenelzine versus imipramine in the treatment of probable atypical depression: Defining syndrome boundaries of selective MAOI responders. American Journal of Psychiatry,.
Reynolds, C. F., Frank, E., Perel, J. M., Imber, S.D., Cornes, C., Miller, M.D., Mazaumdar, S., Houck, P.R., Dew, M. A., Stack, J. A., Pollock, B. G., & Kupfer, D. J. ((1999)). Nortriptyline and interpersonal psychotherapy as maintenance therapies for recurrent major depression: A randomized controlled trial in patients older than 59 years. Journal of the American Medical Association,.
Sackheim, H. A., Prudic, J., Devanand, D. P., Kiersy, J. E., Fizsimons, L., Moody, B. J., McElhiney, M. C., Coleman, E. A., & Settembrino, J. M. ((1993)). Effects of stimulus intensity and electrode placement on the efficacy and cognitive effects of electroconvulsive therapy. New England Journal of Medicine,.
Schulberg, H. C., Block, M. R., Madonia, M. J., Scott, C. P., Rodriguez, E., Imber, S.D., Perel, J., Lave, J., Houck, P. R., & Coulehan, J. L. ((1996)). Treating major depression in primary care pactice: Eight-month clinical outcomes. Archives of General Psychiatry,.
Schweizer, F., Feighner, J., Mandos, L. A., & Rickels, K. ((1994)). Comparison of venlafaxine and imipramine in the acute treatment of major depression in outpatients. Journal of Clinical Psychiatry,.
Shea, M. T., Elkin, I., Imber, S.D., Sotsky, S. M., Watkins, J. T., Collins, J. F., Pilkonis, P. A., Beckham, F., Glass, D. R., Dolan, R. T., et al. ((1992)). Course of depressive symptoms over follow-up: Findings from the NIMH Treatment of Depression Collaborative Research Program. Archives of General Psychiatry,.
Weisler, R. H., Johnston, J. A., Lineberry, C. G., Samara, B., Branconnier, R. J., & Billow, A. A. ((1994)). Comparison of bupropion and trazodone for the treatment of major depression. Journal of Clinical Psychopharmacology,.

## Table A-4: Representation of Minorities in Randomized Controlled Trials for Treatment of AD/HD

Table A-4: Representation of Minorities in Randomized Controlled Trials for Treatment of AD/HD.

Table A-4: Representation of Minorities in Randomized Controlled Trials for Treatment of AD/HD

Study | Sample | Information on ethnicity of sample | Analyses by ethnicity
Fitzpatrick, Klorman, Brumaghim, et al., (1992) | N = 19 (analyzed) | No | No
Srinivas, Hubbard, Quinn, et al., (1992) | N = 9 | No | No
Borcherding, Keysor, Cooper, et al., (1989) | N = 18 | No | No
Castellanos, Giedd, Elia, et al., (1997) | N = 22 | 16 white 2 black 1 Asian 1 Hispanic | No
Efron, Jarman, & Barker, (1997) | N = 125 | No | No
Elia, Borcherding, Rapoport, et al., (1991) | N = 48 | No | No
Matochik, Liebenauer, King, et al., (1994) | N = 37 (analyzed) | No | No
Pelham, Greenslade, Vodde-Hamilton, et al., (1990) | N = 22 | No | No
Rapport, Carlson, Kelly, et al., (1993) | N = 16 | 14 white 2 black | No
Arnold, Kleykamp, Votolato, et al., (1989) | N = 18 (analyzed) | No | No
Klein & Abikoff, (1997) | N = 89 (no break down given) | ?? white ?? African American ?? Hispanic ?? Asian | No
MTA Coop Group, (1999) | N = 579 | 351 white 115 African American 48 Hispanic | No
Levy, Hobbes, (1996) | N = 10 | No | No
Long, Rickert, & Ashcraft, (1993) | N = 32 | No | No
Borden & Brown (1989) | N = 30 | No | No
Brown, Borden, Wynne, et al., (1988) | N= 71 | No | No
Carlson, Pelham, Milich, et al., (1992) | N = 24 | No | No
Hinshaw, Buhrmester, & Heller, (1989) | N = 24 | 17 white 4 black 1 Hispanic 1 Pacific Islander 1 East Indian | No
Pelham, Carlson, Sams, et al., (1993) | N = 31 | 29 white 2 black | No
Solanto, Wender, & Bartell, (1997) | N = 22 | 16 white 5 Hispanic 1 Asian Indian | No
Biederman, Baldessarini, Wright, et al., (1989) a +b | N = 73 | 69 white 4 other | No
Gualtieri, Keenan, & Chandler, (1991) | N = 12 | No | No
Singer, Brown, Quaskey, et al., (1995) | N = 37 (34 completed) | 33 white 1 black | No
Wilens, Biederman, Prince, et al., (1996) | N = 43 | No | No
Gualtieri & Evans, (1988) | N = 9 | No | No
Kupietz, Winsberg, Richardson, et al., (1988) | N = 58 | No | No
Schachar, Tannock, Cunningham, et al., (1997) | N = 91 | No | No
Gillberg, Melander, von Knorring, et al., (1997) | N = 62 | No | No
Fehlings, Roberts, Humphries, et al., (1991) | N = 26 | No | No
Linden, Habib, & Radojevic, (1996) | N = 18 | No | No

### References

Arnold, L. F., Kleykamp, D., Votolato, N. A., Taylor, W. A., Kontras, S. B., & Tobin, K. ((1989)). Gamma-linolenic acid for attention-deficit hyperactivity disorder: Placebo-controlled comparison to d-amphetamine. Biological Psychiatry,.
Biederman, J., Baldessarini, R. J., Wright, V, Knee, D., & Harmatz, J. S. ((1989a)). A double-blind placebo controlled study of desipramine in the treatment of ADD: I. Efficacy. Journal of the American Academy of Child and Adolescent Psychiatry,.
Biederman, J., Baldessarini, R. J., Wright, V., Knee, D., Harmatz, J. S., & Goldblatt, A. (1989b). A double-blind placebo controlled study of desipramine in the treatment ADD: II. Serum drug levels and cardiovascular findings. Journal of the American Academy of Child and Adolescent Psychiatry,.
Borcherding, B. G., Keysor, C. S., Cooper, T. B., & Rapoport, J. L. ((1989)). Differential effects of methylphenidate and dextroamphetamine on the motor activity level of hyperactive children. Neuropsychopharmacology,.
Borden, K. A., & Brown, R. T. ((1989)). Attributional outcomes: The subtle messages of treatments for attention deficit disorder. Cognitive Therapy and Research,.
Brown, R. T., Borden, K. A., Wynne, M. F., & Spunt, A. L. ((1988)). Patterns of compliance in a treatment program for children with attention deficit disorder. Journal of Compliance in Health Care,.
Carlson, C. L., Pelham, W. F. J., Milich, R., & Dixon, J. ((1992)). Single and combined effects of methylphenidate and behavior therapy on the classroom performance of children with attention-deficit hyperactivity disorder. Journal ofAbnormal Child Psychology,.
Castellanos, F. X., Giedd, J. N., Elia, J., Marsh, W. L., Ritchie, G. E, Hamburger, S. D., & Rapoport, J. L. ((1997)). Controlled stimulant treatment of AD/HD and comorbid Tourette's syndrome: Effects of stimulant and dose. Journal of the American Academy of Child and Adolescent Psychiatry,.
Efron, D., Jarman, F., & Barker, M. ((1997)). Methylphenidate versus dexamphetamine in children with attention deficit hyperactivity disorder: A double-blind, crossover trial. Paediatrics,.
Elia, J., Borcherding, B. G., Rapoport, J. L., & Keysor, C. S. ((1991)). Methyiphenidate and dextroamphetamine treatments of hyperactivity: Are there true nonresponders?. Psychiatry Research,.
Fehlings, D. L., Roberts, W., Humphries, T., & Dawe, G. ((1991)). Attention deficit hyperactivity disorder: Does cognitive behavioral therapy improve home behavior?. Journal of Developmental and Behavioral Pediatrics,.
Fitzpatrick, P A., Klorman, R., Brumaghim, J. T., & Borgstedt, A. D. ((1992)). Effects of sustained-release and standard preparations of methylphenidate on attention deficit disorder. Journal of the American Academy of Child and Adolescent Psychiatry.
Gillberg, C., Melander, H., von Knorring, A. L., Janols, L.0., Thernlund, G., Hagglof, B., Fidevall-Wallin, L., Gustafsson, P., & Kopp, 5. ((1997)). Long-term stimulant treatment of children with attention-deficit hyperactivity disorder symptoms. A randomized, double-blind, placebo-controlled trial. Archives of General Psychiatry.
Gualtieri, C. T., & Evans, R. W. ((1988)). Motor performance in hyperactive children treated with imipramine. Perceptual and Motor Skills,.
Gualtieri, C. T., Keenan, P. A., & Chandler, M. ((1991)). Clinical and neuropsychological effects of desipramine in children with attention deficit hyperactivity disorder. Journal of Clinical Psychopharmacology,.
Hinshaw, S. P., Buhrmester, D., & Heller, T. ((1989)). Anger control in response to verbal provocation: Effects of stimulant medication for boys with AD/HD. Journal of Abnormal Child Psychology,.
Klein, R. G., & Abikoff, H. ((1997)). Behavior therapy and methyiphenidate in the treatment of children with AD/HD. Journal of Attention Disorders,.
Kupietz, S. S., Winsberg, B. G., Richardson, F., Maitinsky, 5. ((1988)). Effects of methylphenidate dosage in hyperactive reading-disabled children: I. Behavior and cognitive performance effects. Journal of the American Academy of Child and Adolescent Psychiatry,.
Levy, F, & Hobbes, G. ((1996)). Does haloperidol block methylphenidate? Motivation or attention?. Psychopharmacology,.
Linden, M., Habib, T., & Radojevic, V. ((1996)). A controlled study of the effects of EEG biofeedback on cognition and behavior of children with attention deficit disorder and learning disabilities. Biofeedback and Self-Regulation,.
Long, N., Rickert, V. I., & Ashcraft, F.W. ((1993)). Bibliotherapy as an adjunct to stimulant medication in the treatment of attention-deficit hyperactivity disorder. Journal of Pediatric Health Care,.
Matochik, J. A., Liebenauer, L. L., King, C., Szymanski, H. V., Cohen, R. M., & Zametkin, A. J. ((1994)). Cerebral glucose metabolism in adults with attention deficit hyperactivity disorder after chronic stimulant treatment. American Journal of Psychiatry,.
MTA Cooperative Group. ((1999)). 14-month randomized clinical trial of treatment strategies for attention deficit hyperactivity disorder. Multimodal treatment Study of Children with AD/HD. Archives of General Psychiatry,.
Pelham, W. E. J., Carlson, C., Sams, S.F., Vallano, G., Dixon, M. J., & Hoza, B. ((1993)). Separate and combined effects of methylphenidate and behavior modification on the classroom behavior and academic performance of AD/HD boys: Group effects and individual differences. Journal of Consulting and Clinical Psycology;.
Pelham, W. F. J., Greenslade, K. E., Vodde-Hamilton, M., Murphy, D. A., Greenstein, J. J., Gnagy, F.M., Guthrie, K. J., Hoover, M. D., & Dahl, R. F. ((1990)). Relative efficacy of long-acting stimulants on children with attention deficit-hyperactivity disorder: A comparison of standard methylphenidate, sustained-release methylphenidate, sustained-release dextroamphetamine, and pemoline. Pediatrics.
Rapport, M. D., Carlson, G. A., Kelly, K. L., & Pataki, C. ((1993)). Methylphenidate and desipramine in hospitalized children: 1. Separate and combined effects on cognitive function. Journal of the American Academy of Child and Adolescent Psychiatry,.
Schachar, R. J., Tannock, R., Cunningham, C., & Corkum, P. V. ((1997)). Behavioral, situational, and temporal effects of treatment of AD/HD with methylphenidate. Journal of the American Academy of Child and Adolescent Psychiatry,.
Singer, H. S., Brown, J., Quaskey, S., Rosenberg, L. A., Mellits, F. D., & Denckla, M. B. ((1995)). The treatment of attention-deficit hyperactivity disorder in Tourette's syndrome: A double-blind placebo-controlled study with clonidine and desipramine. Pediatrics,.
Solanto, M. V., Wender, F. H., & Bartell, S. 5. ((1997)). Effects of methylphenidate and behavioral contingencies on sustained attention in attention-deficit hyperactivity disorder: A test of the reward dysfunction hypothesis. Journal of Child and Adolescent Psychopharmacology,.
Srinivas, N. R., Hubbard, J. W., Quinn, D., & Midha, K. K. ((1992)). Enantioselective pharmacokinetics and pharmacodynamics of dl-threo-methylphenidate in children with attention deficit hyperactivity disorder. Clinical Pharmacological Therapy,.
Wilens, T. F., Biederman, J., Prince, J., Spencer, T. J., Faraone, S. V., Warburton, R., Schleifer, D., Harding, M., Linehan, C., & Geller, D. ((1996)). Six-week, double-blind, placebo-controlled study of desipramine for adult attention deficit hyperactivity disorder. American Journal of Psychiatry,.