# Conference Information

Surgeon General's Conference on Children's Mental Health: Developing a National Action Agenda September 18-19, 2000 Sponsored by DEPARTMENT OF HEALTH AND HUMAN SERVICES Office of the Surgeon General, Office of Public Health and Science National Institute of Mental Health, National Institutes of Health Center for Mental Health Services, Substance Abuse and Mental Health Services Administration Assistant Secretary for Planning and Evaluation, Office of the Secretary National Center for Environmental Health, Centers for Disease Control and Prevention Food and Drug Administration Maternal and Child Health Bureau, Health Resources and Services Administration National Institute on Drug Abuse, National Institutes of Health DEPARTMENT OF EDUCATION Office of Special Education Programs, Office of Special Education and Rehabilitative Services DEPARTMENT OF JUSTICE Office of Juvenile Justice and Delinquency Prevention, Office of Justice Programs In collaboration with Office of Safe and Drug-Free Schools, Office of Elementary and Secondary Education, Department of Education Administration on Children, Youth and Families, Administration for Children and Families, Department of Health and Human Services Health Care Financing Administration, Department of Health and Human Services National Institute of Child Health and Human Development, National Institutes of Health, Department of Health and Human Services