# Acknowledgements

This report was prepared by the Department of Health and Human Services in collaboration with the Department of Education and the Department of Justice. It is an outgrowth of the Surgeon General's Report on Mental Health which was released in December, 1999.

Interdepartmental Planning Committee Co-chairs Beverly L. Malone, Ph.D, RN, FAAN Deputy Assistant Secretary for Health Office of Public Health and Science Kimberly Hoagwood, Ph.D. Associate Director for Child and Adolescent Research National Institute of Mental Health Coordinating Editor S. Serene Olin, Ph.D. Members Coleen Boyle, Ph.D. Terry Cline, Ph.D. Marsha Davenport, M.D. Connie Deshpande, B.A., M.P.A. Margaret Feerick, Ph.D. Jerry Flanzer, D.S.W. Norma Hatot, Capt, USPHS Lynne Haverkos, M.D., M.P.H. Kelly Henderson, Ph.D. Judith Katz-Leavy, M.Ed. Woodie S. Kessel, M.D., M.P.H. Catherine A. Lesesne, M.P.H. Peggy McCardle, Ph.D., M.P.H. Suzanne Martone, M.P.A. Martha Moorehouse, Ph.D. Eve Moscicki, Sc.D., M.P.H. Dianne Murphy, M.D. Allan S. Noonan, M.D., M.P.H. Delores Parron, Ph.D. William Rodriguez, M.D. Rolando Santiago, Ph.D. Karen Stern, Ph.D. Frank Sullivan, M.D. John J. Tuskan, Jr., R.N., M.S.N. Other Contributors Betty James Damon Thompson Marilyn Weeks Clarissa Wittenberg Daisy Whittemore Catherine West

Substantial public input was sought and received at multiple steps in the process of developing the action agenda for children's mental health. Special thanks to all who contributed to the national dialogue on children's mental health, especially to:

- All who provided input through the World Wide Web and the mail;
- Participants at the Surgeon General's Listening Session; and
- Participants at the Surgeon General's Conference on Children's Mental Health, especially the youth whose input reminded us of the critical need to listen to their perspectives.

Special thanks to the leadership and staff of the Office of Public Health and Science for their enthusiastic support of this interdepartmental effort.

- Nicole Lurie, M.D., M.S.P.H.,
- Principal Deputy Assistant Secretary for Health
- Kenneth Moritsugu, M.D., M.P.H.,
- Deputy Surgeon General, USPHS