# Conference Summary

## Background

The nation is facing a public crisis in mental healthcare for infants, children and adolescents. Many children have mental health problems that interfere with normal development and functioning. In the United States, one in ten children and adolescents suffer from mental illness severe enough to cause some level of impairment (Burns, et al., 1995; Shaffer, et al., 1996). Yet, in any given year, it is estimated that about one in five of such children receive specialty mental health services (Burns, et al., 1995). Unmet need for services remains as high now as it was 20 years ago. Recent evidence compiled by the World Health Organization indicates that by the year 2020, childhood neuropsychiatric disorders will rise proportionately by over 50 percent, internationally, to become one of the five most common causes of morbidity, mortality, and disability among children.

Concerns about inappropriate diagnosis -- that is, either over- or under-diagnosis -- of children's mental health problems and about the availability of evidence-based (i.e., scientifically-proven) treatments and services for children and their families have sparked a national dialogue around these issues. There is broad evidence that the nation lacks a unified infrastructure to help these children, many of whom are falling through the cracks. Too often, children who are not identified as having mental health problems and who do not receive services end up in jail. Children and families are suffering because of missed opportunities for prevention and early identification, fragmented treatment services, and low priorities for resources.

To address these critical issues, the Office of the Surgeon General held a conference on Children's Mental Health: Developing a National Action Agenda on September 18-19, 2000 in Washington, DC. This conference represented an extraordinary level of collaboration among three major Federal Departments: the Department of Health and Human Services, the Department of Justice, and the Department of Education. The purpose of the conference was to engage a group of citizens in a thoughtful, meaningful dialogue about issues of prevention, identification, recognition, and referral of children with mental health needs to appropriate, evidence-based treatments or services. The 300 invited presenters and participants represented a broad cross-section of mental health stakeholders, including those from primary care, education, juvenile justice, child welfare, and substance abuse systems. Disciplines represented included education, pediatrics, social work, psychiatry, psychology, nursing, public health, and faith-based practitioners. Individuals representing associations, advocacy groups, the scientific community, members of the healthcare industry, clinicians, healthcare providers, families and youth attended this conference.

This conference is one piece of a national conversation addressing the mental health needs of our Nation's children. The White House Conference on Mental Health, in June 1999, was the first major public orientation to the realities of mental illness in the United States. This was followed by the Surgeon General's Call to Action to Prevent Suicide in July 1999, and the release of a first-ever Surgeon General's Report on Mental Health in December 1999. This report addressed complex issues in mental health and included a chapter on the mental health of children. Most recently, in March 2000, the White House held another meeting specifically addressing the need to improve the diagnosis and treatment of children with emotional and behavioral conditions. Following this conference, the National Institute of Mental Health and the Food and Drug Administration held a meeting in October 2000, focusing on research needed to develop psychopharmaceuticals for young children.

The agenda for this meeting was developed with extensive input from a broad range of interested individuals. In May, public input was solicited through the World Wide Web and mailings to over 500 individuals. Nearly 400 responses were received within a month. On June 26, 50 individuals were invited to a formal Listening Session with the Surgeon General to help craft the agenda for this conference. Key issues of concern to families, service providers, and researchers were identified, and included:

- Educating the public about mental health and illness in children;
- Ensuring screening and early identification of children within key service systems;
- Implementing evidence-based treatments and services;
- Providing adequate and appropriate education and training to frontline providers;
- Engaging families in all aspects of service delivery; and
- Continuing to build the research base on children's mental health.

The conference agenda was thus developed to address these major concerns, with the aim of addressing the need to improve the state of children's mental health and their families'. To initiate national dialogue about children's mental health concerns, conference participants listened to plenary sessions in which leaders in the field, including youth and family members themselves, briefly outlined key issues involved in:

- Identifying, recognizing, and referring children with mental health needs in key services systems;
- Health services disparities: increasing access to services through family engagement and reducing disparities in access; and
- State of the evidence in treatments, services, systems of care and financing: the gap between what we know and what we do.

These presentations, summarized below, provided conference participants with information to engage in meaningful discussions on children's mental health issues. Conference participants were divided into 10 working groups over the two days. To help develop consensus recommendations, participants aided by selected facilitators and recorders, were asked to:

- Identify the barriers to appropriate identification and recognition of children with mental health needs and the factors that impede access to appropriate treatments or services;
- Identify major opportunities for promoting child and adolescent mental health and for preventing risks and antecedents associated with mental illness;
- Identify the major policies that offer opportunity for strengthening recognition and improving access to care;
- Identify professional training needs in child and adolescent mental health;
- Identify the major barriers to implementing evidence-based treatments and services; and
- Develop recommendations for bridging the gaps among research, practice, and policy.

Facilitators and recorders of each group helped group members prioritize their recommendations, and came together each day of the conference to synthesize the input from their respective groups.

Consensus among the top recommendations was developed, and these were presented to the Surgeon General and the conference participants. Youths present at the conference formed their own group, and presented their input directly to the Surgeon General and the participants as well.

Conference participants also had the opportunity to directly address Dr. Satcher, and to provide their comments. These recommendations, together with those developed from the NIMH/FDA meeting on Psychopharmacology for Young Children: Clinical Needs and Research Opportunities, were used as a basis for the development of the Surgeon General's National Action Agenda for Children's Mental Health.