# Goals

1. Promote public awareness of children's mental health issues and reduce stigma associated with mental illness.
2. Continue to develop, disseminate, and implement scientifically-proven prevention and treatment services in the field of children's mental health.
3. Improve the assessment of and recognition of mental health needs in children.
4. Eliminate racial/ethnic and socioeconomic disparities in access to mental healthcare services.
5. Improve the infrastructure for children's mental health services, including support for scientifically-proven interventions across professions.
6. Increase access to and coordination of quality mental healthcare services.
7. Train frontline providers to recognize and manage mental health issues, and educate mental healthcare providers about scientifically-proven prevention and treatment services.
8. Monitor the access to and coordination of quality mental healthcare services.

## Goal 1: Promote public awareness of children's mental health issues and reduce stigma associated with mental illness

### Action Steps

- Promote social, emotional, and behavioral well-being as an integral part of a child's healthy development.
- Develop and/or disseminate existing guidelines on how to enhance child development, including mental health. Different sets of guidelines will need to be created for the general public, families, parents and caregivers, and professional groups.
- Identify early indicators for mental health problems.
- Integrate mental health consultations as part of children's overall general healthcare and advise healthcare providers regarding the importance of assessing mental health needs.
- Develop a national capacity to provide adequate preventive mental health services.
- Conduct a public education campaign to address the stigma associated with mental health disorders. This could be accomplished through partnerships with the media, youth, public health systems, communities, health professionals, and advocacy groups.

## Goal 2: Continue to develop, disseminate, and implement scientifically-proven prevention and treatment services in the field of children's mental health

### ACTION STEPS

- Support basic research on child development, and use current knowledge about neurological, cognitive, social, and psychological development to design better screening, assessment, and treatment tools and develop prevention programs.
- Support research on familial, cultural, and ecological contexts to identify opportunities for promoting mental health in children and providing effective prevention, treatment, and services.
- Support research in developmental psychopathology to help clarify diagnoses and provide methodology that is sensitive, specific, and that can be used in designing and interpreting pharmacological and other clinical trials.
- Support research in basic and clinical neuroscience to provide better information and understanding of pharmacogenetics and ontogeny of drug effects on the developing brain in the short term, as well as the long-term consequences of pharmacological intervention associated with both acute and chronic exposure.
- Support research on legal/ethical and confidentiality issues associated with the treatment of children and families.
- Support research to develop and test innovative behavioral, pharmacological, and multimodal interventions.
- Increase research on proven treatments, practices, and services developed in the laboratory to assess their effectiveness in real-world settings.
- Study the nature and effectiveness of clinical practices in real-world settings.
- Assess the short- and long-term outcomes of prevention and treatment efforts, including the effect of early intervention on the prognosis and course of mental illness.
- Promote research on factors that facilitate or impede the implementation and dissemination of scientifically-proven interventions.
- Support research evaluating the process and impact of promising policies and programs, including cost-effectiveness research (e.g., EPSDT, IDEA, Head Start, SCHIP [see Appendix B]).
- Evaluate the impact of organization and financing of services on access, the use of scientifically-proven prevention and treatment services, and outcomes for children and families.
- Develop and evaluate model programs that can be disseminated and sustained in the community.
- Build private and public partnerships to facilitate the dissemination and cross-fertilization of knowledge.
- Create a forum for promoting direct communication among researchers, providers, youth and families to bridge the gap between research and practice.
- Create a standing workgroup for the purpose of identifying research opportunities, discussing potential approaches, monitoring progress in the area of psychopharmacology for young children, and addressing ethical issues regarding research with children. This group should include representatives of all interested parties, such as researchers, practitioners, youth and families, industry, and federal regulatory, research, and services agencies.
- Create an oversight system to identify and approve scientifically-based prevention and treatment interventions, promote their use, and monitor their implementation.

## Goal 3: Improve the assessment of and recognition of mental health needs in children

### ACTION STEPS

- Encourage early identification of mental health needs in existing preschool, childcare, education, health, welfare, juvenile justice, and substance abuse treatment systems.
- Create tangible tools for practitioners in these systems to help them assess children's social and emotional needs, discuss mental health issues with parents or caregivers and children, and make appropriate referrals for further assessments or interventions.
- Train all primary healthcare providers and educational personnel in ways to enhance child mental health and recognize early indicators of mental health problems in children with special healthcare needs, children of fragmented families, and children of parents with mental health and/or substance abuse disorders.
- Promote cost-effective, proactive systems of behavior support at the school level. These systems of behavior support should emphasize universal, primary prevention methods that recognize the unique differences of all children and youth, but should include selective individual student supports for those who have more intense and long-term needs.
- Increase provider understanding of children's mental healthcare needs and provide training to address the various mental health issues among children with special healthcare needs and their families.
- Increase the understanding of practitioners, policymakers, and the public of the role that untreated mental health problems play in placing children and youth at risk for entering the juvenile justice system.

## Goal 4: Eliminate racial/ethnic and socioeconomic disparities in access to mental healthcare services

### ACTION STEPS

- Increase accessible, culturally competent, scientifically-proven services that are sensitive to youth and family strengths and needs.
- Increase efforts to recruit and train minority providers who represent the racial, ethnic, and cultural diversity of the country.
- Co-locate mental health services with other key systems (e.g., education, primary care, welfare, juvenile justice, substance abuse treatment) to improve access, especially in remote or rural communities.
- Strengthen the resource capacity of schools to serve as a key link to a comprehensive, seamless system of school- and community-based identification, assessment and treatment services to meet the needs of youth and their families where they are.
- Encourage the development and integration of alternative, testable approaches to mental healthcare that engage families in prevention and intervention strategies (e.g., pastoral counseling).
- Develop policies for uninsured children across diverse populations and geographic areas to address the problem of disparities in mental health access.
- Develop and support mental health programs designed to divert youth with mental health problems from the juvenile justice system.
- Increase research on diagnosis, prevention, treatment, and service delivery issues to address disparities in access to mental healthcare services, especially among different racial, ethnic, gender, sexual orientation, and socioeconomic groups.

## Goal 5: Improve the infrastructure for children's mental health services, including support for scientifically-proven interventions across professions

### ACTION STEPS

- Encourage the health system to respond to mental health prevention and treatment service needs through universal, comprehensive, and continuous health coverage.
- Review both the incentives and disincentives for healthcare providers to assess children's mental health needs, including preventive interventions, screening, and referral.
- Provide the infrastructure for cost-effective, cross-system collaboration and integrated care, including support to healthcare providers for identification, treatment coordination, and/or referral to specialty services; and the development of integrated community networks to increase appropriate referral opportunities.
- Provide incentives for scientifically-proven and cost-effective prevention and treatment interventions that are organized to support families, and that consider children and their caregivers as a basic unit (e.g., family therapy, home-based treatment, intensive case management).
- Create incentives and support for agencies, programs and individual practitioners to develop and utilize science-based strategies and interventions in community settings.
- Determine which policies and programs for children are most cost-effective and improve access to quality care, especially among the uninsured.

## Goal 6: Increase access to and coordination of quality mental healthcare services

### ACTION STEPS

- Develop a common language to describe children's mental health, emphasizing adaptive functioning and taking into account ecological, cultural, and familial context. A common language is important to facilitate service delivery across systems.
- Develop a universal measurement system across all major service sectors that is age-appropriate, culturally-competent, and gender sensitive to (i) identify children, including those with special healthcare needs, who may need mental health services; (ii) track child progress during treatment; and (iii) measure treatment outcomes for individual patients.
- Modify definitions and evaluation procedures used by education systems to identify and serve children and youth who have mental health needs. These definitions and procedures should facilitate access to, not exclusion from, essential services.
- Provide access to services in places where youth and families congregate (e.g., schools, recreation centers, churches, and others).
- Support the development of coordinated responses by emergency medical providers (e.g., paramedics, emergency room personnel) and community mental health service providers to expedite appropriate treatment and/or referral for children presenting with emergency and traumatic episodes in hospital emergency rooms.
- Address issues of confidentiality in ways that respect a family's right to privacy, but encourage the coordination and collaboration among providers in different systems.
- Encourage family organizations to help family members access information on enhancing children's mental health and the availability of effective treatments for mental illness so that they can make fully-informed decisions about interventions offered.
- Include youth in treatment planning by offering them direct information, in developmentally appropriate ways, about treatment options. As much as possible, allow youth to make decisions and choices about preferred intervention strategies.
- Use family advocates, such as family members with prior experience, to assist families in interacting effectively with complicated service systems such as healthcare, education, juvenile justice, child welfare, and substance abuse treatment.
- Provide a mechanism for input from youth and families in setting a national mental health agenda and in assessing policies and programs to promote mental health services delivery.

## Goal 7: Train frontline providers to recognize and manage mental healthcare issues, and educate mental health providers about scientifically-proven prevention and treatment services

### ACTION STEPS

- Engage professional organizations in educating new frontline providers in various systems (e.g., teachers, physicians, nurses, hospital emergency personnel, daycare providers, probation officers, and other child healthcare providers) in child development; equip them with skills to address and enhance children's mental health; and train them to recognize early symptoms of emotional or behavioral problems for proactive intervention. Such training must focus on developmental and cultural differences in cognitive, social, emotional, and behavioral functioning, and understanding these issues in familial and ecological context.
- Facilitate training of new providers by building knowledge of child development into the existing curricula of professional programs and encouraging on-going training opportunities across disciplines to facilitate the development of effective partnerships.
- Develop and evaluate multidisciplinary programs for healthcare professionals that focus on child and family mental health.
- Create training support for professionals, paraprofessionals, and family advocates to keep abreast of new developments in the field of children's mental health.
- Address the shortage of well-trained child mental health specialists, particularly minority individuals, by encouraging active recruitment and the provision of incentive programs by professional organizations, federal programs, and federal legislation, and consider the development of training programs for mid-level providers in mental health to address inadequate capacity.
- Encourage professional boards for mental health specialists (e.g., psychiatry, psychology, social work, and nursing) to require training in: evidence-based prevention and treatment interventions; outcome-based quality assurance; competency-based assessment and diagnostic skills; principles of culturally-competent care; and engaging youth and families as partners in assessment, intervention, and outcome monitoring.
- Provide mechanisms to monitor and evaluate efforts to train new professionals, retrain existing professionals, and examine the effectiveness of these training efforts.

## Goal 8: Monitor the access to and coordination of quality mental healthcare services

### ACTION STEPS

- Establish formal partnerships among federal research, regulatory, and service agencies, professional associations and families and caregivers to facilitate the transfer of knowledge among research, practice, and policy related to children's mental health.
- Encourage behavioral healthcare industry and service agencies to develop and use broad-based outcome and process measures to ensure accountability. These measures should be relevant and meaningful, such as symptom severity, adaptive functioning, family satisfaction, and societal/economic costs and benefits in terms of involvement in systems such as special education, welfare, and juvenile justice.
- Develop national quality improvement protocols that emphasize the use of scientifically-proven practices and evaluate the effectiveness of service systems.
- Encourage providers to inform consumers about evidence for and against the effectiveness of proposed treatments and services.
- Make available information on effective prevention and treatment interventions through federal partners, professional organizations, family organizations, and private foundations. In addition, provide information that will allow practitioners to evaluate the worth of promising interventions.
- Encourage industry and service agencies to develop a variety of mechanisms for consumers to communicate their experiences and concerns to funding agencies and purchasers of healthcare plans (i.e., federal, state and local governments and private employers).
- Monitor efforts to coordinate services and reduce mental health access disparities through public health surveillance and evaluation research.

## Proceedings based on the Surgeon General's Conference on Children's Mental Health: Developing a National Action Agenda