# Appendix A

## References

Burnam, M.A. and Escarce, J.J. (1999) Equity in managed care for mental disorders Health Affair 18(5) 22 31
Burns, B.J.; Costello, E.J.; Angold, A.; Tweed, D.; Stangl, D.; Farmer, E.M.Z. and Erkanli, A. (1995) DataWatch: Children's Mental Health Service Use Across Service Sectors Health Affair 14(3) 147 159
CBS. 1997.
Costello, E.J.; Angold, A.; Burns, B.J.; Erkanli, A.; Stangl, D.K; and Tweed, D.L. (1996) The Great Smokey Mountains Study of youth: Functional impairment and serious emotional disturbance Archives of General Psychiatry 53(12) 1137 1143
Greenberg, M.T.; Domitrovich, C.; and Bumbarger, B. (1999). Preventing mental disorder in school-aged children: A review of the effectiveness of prevention programs.
NAMC 1998 National Ambulatory Medical Care Survey: 1998 Summary. Advance data from vital and health statistics, No. 315 , Hyattsville,, MD. National Center for Health Statistics 2000
Roberts, R.E.; Attkisson, C.C.; and Rosenblatt, A. (1998) Prevalence of psychopathology among children and adolescents American Journal of Psychiatry 155(6) 715 25
Shaffer, D.; Fisher, P. Dulcan, M.K.; Davies, M.; Piacentini, J.; Schwab-Stone, M.E.; Lahey, B.B.; Bourdon, K.; Jensen, P.S.; Bird, H.R.; Canino, G. and Regier, D.A. (1996) The NIMH Diagnostic Inverview Schedule for Children Version 2.3 (DISC-2.3): Description, acceptability, prevalence rates, and performance in the MECA study Journal of the American Academy of Child and Adolescent Psychiatry 35(7) 865 877
Sturm, R. (1997) How expensive is unlimited mental health care coverage under managed care? Journal of the American Medical Association 278(18) 1533 7
Wells, K.B.; Sherbourne, C.; Schoenbaum, M.; Duan, N.; Meredith, L.; Unutzer, J.; Miranda J.; Carney, M.F.; and Rubenstein, L.V. (2000) Impact of disseminating quality improvement programs for depression in managed primary care: a randomized controlled trial Journal of the American Medical Association 283(2) 212 20
Zito, J.M.; Safer, D.J.; dosReis, S.; Gardner, J.F.; Boles, M.; and Lynch, F. (2000) Trends in the prescribing of psychotropic medications to preschoolers Journal of the American Medical Association 283(8) 1025 30