# References

1 Institute of Medicine. 2013. Best Care at Lower Cost: The Path to Continuously Learning Health Care in America. Washington, DC: The National Academies Press. https://doi.org/10.17226/13444.
2 The Learning Healthcare Project. http://www.learninghealthcareproject.org/section/background. Accessed September 13 2017.
3 McGinnis JM. Evidence-based medicine - engineering the Learning Healthcare System. Stud Health Technol Inform. 2010;153:145-57. PMID: 2054324320543243
4 Smith S, Gerlach L and O'Brien E. The AcademyHealth Listening Project: Improving the Evidence Base for Safety Net Health Care Delivery. AcademyHealth, February 2016.
5 Villa L, Warholak TL, Hines LE, . Health care decision makers' use of comparative effectiveness research: report from a series of focus groups. J Manag Care Pharm 2013;19:745-54. http://dx.doi.org/10.18553/jmcp.2013.19.9.745.24156643