# Recommendations

The EPC/AHRQ working group assessed the key themes that were brought up by the KI and recommend several possible changes for consideration to the EPC Program:

1. Modify the dissemination emails that go out to health-systems to include not only the titles of the reports and hyperlinks to the full reports, but to include key messages (or hyperlinks to key messages) so that potential users can better assess the relevance of their report to their decision making and better triage the findings internally within their system.
2. Periodically construct an EPC newsletter — perhaps building off the existing EHC listerv — with a format similar to “The Medical Letter” or “Prescriber's Letter,” which provides short three of four sentence summaries of report highlights with hyperlinks to reports.
3. Ensure that EPC reports are searchable both within PubMed but also within common search engines such as Google, Bing, and Yahoo. This would include having medical librarians test search using these sites, strategize how to enhance the chances of finding reports for educational purposes, and to reach out to the common search engines and inquire about ways reports can be designed to enhance pick up in searches.
4. Explore opportunities to deliver reports more quickly, perhaps through further limiting the scope of a project, writing more focused reports, or by dividing a larger topic into two or three subtopics so that more timely evidence can be available to health-system decision makers.
5. EPC reports should not make clinical recommendations like guidelines. However, if the reports could more clearly identify what the current process of care is for a target disease or disorder and where the trials/studies being summarized or pooled will inform decisions that members of health-systems could make, it would make the results more actionable.
6. Conduct broad outreach to health-systems to alert them of the topic nomination process so that these topics can be considered within the EPC program and discuss partnerships not unlike those AHRQ has with guideline groups and other federal agencies. AHRQ and the EPCs can begin with the contacts made with health-systems from this project, contacts identified from the Spring 2017 EPC meeting, and contacts identified from the health-systems which have EPCs to form an advisory group and devise a strategy.
7. Establish consistent and prominent branding of the EPC program and its products, ensure that the high-quality journal articles based on our reports are identified as part of the EPC program, and promote the EPC program as a source for timely and reliable reports to improve the quality, safety, and value of care.