# Purpose

To better understand how health-systems get and use evidence and how EPC reports could help them with their decisionmaking in the future.

More specifically, the purpose of this EPC methods project is to understand health-systems' processes for reviewing and using evidence:

- Sources of evidence
- Preferred format of evidence
- Gaps in evidence used
- Topics most interested in
- Familiarity with AHRQ EPC program