# Procedure

In February 2017, AHRQ convened a Workgroup with members from across the EPCs and AHRQ. The project involved: (1) determining what the Workgroup and the EPC Program wanted to learn through this project, (2) identifying potential health-system leaders for interviews, (3) generating a semi-structured interview guide, (4) conducting interviews, and (5) analyzing the qualitative interview data and summarizing it in this report. Appendix A contains the interview guide.

Workgroup investigators conducted interviews with nine individuals with leadership roles in enhancing health-system quality, safety, and process improvement from academic, non-academic, and small community health-systems, as well as health-system collaborative organizations (see Table 1 for a list of Key Informants).

Table 1 Overview of Participating Health-Systems

Health-System | Description of Health-System | Titles of Key Informants
Duke University | Single academic health-system with 3 hospitals, >70 primary care clinics, and Accountable Care Organization in North Carolina | Director of Care Redesign Director of Safety & Quality Programs
Mayo Clinic | Single academic health-system with >8 hospitals, 10 critical access hospitals, primary care clinics in Minnesota, Arizona, Florida, Wisconsin, and Iowa (part of HVHC, see below) | Associate Dean for Value Creation
Catholic Health Initiatives (CHI) | Third largest nonprofit health-system in the United States with health centers ranging from academic to small/rural; comprised of 104 hospitals in 19 states, community clinics, and living communities | Chief Quality Officer Vice President of Analytics Head, Cardiovascular Service Line
(OCHIN): Winding Waters Community Health Center and Cowlitz Family Health Center | Two independent health-systems (one in Oregon and one in Washington) which are part of OCHIN, one of the largest health information and innovation networks, serving hundreds of organizations and over 10,000 clinicians nationwide | Medical Director Executive Director
High Value Healthcare Collaboration (HVHC) and Intermountain Healthcare | HVHC is a 15 health-system partnership ranging from academic to nonacademic from across the country in a data sharing partnership Intermountain is a single health-system with 22 hospitals and 180 clinics in Utah and Idaho that partners with HVHC | Chair of HVHC and Chief Quality Officer at Intermountain

A primary and secondary facilitator conducted each interview and a notetaker took notes of the discussion. Most interviews were also audio recorded. After each interview, one of the facilitators summarized the discussion and shared it with the other interviewer and notetaker to identify and correct areas of disagreement and/or refinement. Workgroup members reviewed the meeting notes, transcripts, and summaries to identify the key themes, which are summarized in this report. When possible, differences and commonalities in themes based on the type of health-system (e.g., academic vs small community) are described. The recommendations were developed based on suggestions from Key Informants (KI) as well as Workgroup analysis of the key themes. The Workgroup shared the draft report with the nine KIs to ensure clarity of message and fidelity of the key points.