# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: (1) Elizabeth Powers, M.D. (Winding Water Community Health Center, OCHIN); (2) Gerardo Melgar, M.D. (Cowlitz Family Health Center, OCHIN); (3) Jonathan Bae, M.D. (Duke University Medical Center); (4) George Cheely Jr., M.D., M.B.A. (Duke University Medical Center); (5) James Reichert, M.D., Ph.D. (Catholic Health Initiatives); (6) Camille Haycock, R.N. (Catholic Health Initiatives); (7) Jerome Granato, M.D. (National Cardiovascular Service Line, Catholic Health Initiatives); (8) Paula Santrach, M.D. (Mayo Clinic); and (9) Brent James, M.D. (High Value Healthcare Collaborative and Intermountain Healthcare). These individuals generously agreed to participate in individual interviews on which our results are based.