# Feedback From Health-System Key Informants

In this section we summarize the key themes from the interviews, each key theme is bolded and direct quotes are italicized.

## Process for Reviewing and Using Evidence

At the start of each interview, the faciliators asked about the current process for identifying, reviewing, and using evidence in their health-system to inform decisionmaking. The processes varied but generally consisted of one of the following methods.

Using centralized performance improvement processes. All of the health-systems we spoke with have either centralized and standardized quality, safety, and process improvement functions within their health-system or have formed partnerships with other organizations to support these improvements. They also expressed that they expect the degree of integration of these function in or between health-systems to accelerate over time.

The joke a couple years ago was that we were fully integrated on the brochure, but we want to be fully integrated through a management philosophy. We are and we've taken huge steps in that direction already: we've centralized our performance management team, we've created a health-system quality department.

Using targeted literature searches for identifying evidence. One of the common processes used was to obtain information and evidence from the literature. However, there was variation in how this information was obtained. Some of the larger health-systems had medical librarians and centralized committees to gather and disseminate this information. For smaller systems, it was more common that the local chief medical officers or clinical champions identified the information. Some of the larger health-systems noted that identifying evidence can be challenging and having staff with experience doing such searches can be very valuable.

We have more consistently integrated people who are experts in kind of navigating the vast volumes of information that's out there, to help put together an evidence-based solution.

While Medline and other medical literature databases were commonly used to identify relevant literature, Google searches were used to identify evidence as well, especially in small and rural health-systems with less access to medical librarians. Smaller health-systems did not have the ability to access to Medline, Cochrane Central, or Embase. KIs noted that they liked how articles identified by Google can be easily shared among the clinicians in a health-system via weblinks.

I don't have a primary subscription to those, and I can just Google recommendations on COPD and it shows up, so something I can find on Google that's high-quality evidence is definitely going to be used.

We post things to the resource library and provide links to national standards.

Using benchmarking data to compare performance and drive improvements. Some KIs noted that their system had a centralized process to compare national standard of care to local and peer performance. They felt the ability to identify exemplar hospitals or clinics within a health-system or an examplar health-system within a consortium of health-systems to compare and contrast their processes which was seen as a big advantage. This prevents health-systems from having to start from scratch, since they can see what is working well in the exemplar sites.

All of us as systems are being held accountable under CMS, from Medicare particularly, for a series of quality measures.

For any measure, we'll nearly always have some members… that are just absolutely nailing them. So, on percentile rankings, up in the high 90s. For others, you'll do more poorly in… We know where we rank, but far more important—way, far more important is what we do next, is we take those rankings and we go to the top end systems and say, “What are you doing? Why are you ranked highly?”

Larger health-systems utilize Vizient Reports, Procured Health Reports, ECRI's Top Threat Report, National Patient Safety Foundation (NPSF) Newsletter, IHI Newsletter, and the AHRQ Newsletter to identify new areas where they can identify metrics to benchmark or to reach out to high achieving systems for insight. The small/rural KIs did not have access to these specialized services. If they try to standardize care, they rely more on national guidelines issued by professional societies.

I've used the AHRQ Newsletter, or the NPSF Newsletter, or the IHI Newsletter. I use those things as they come in, in an unstructured way to say, like, "Ooh, do we need to be thinking about that?" and then push some of those thoughts and thinking—or like the ECRI Top 10 Safety Concerns Report, that's the one we're talking about now.

Using inter-professional committees within a medical subspecialty to understand the issue, the current care process, and make recommendations for process improvement. KIs using inter-professional committees felt they were in the best position to drive changes in the processes. The KIs from health-systems using this model felt that the representatives on the inter-professional committee are actively treating patients within their subspecialty (i.e. cardiology, oncology, orthopedics), have first-hand knowledge of the processes and the reasons current processes evolved in this manner, and will be directly impacted by the remedies they recommend.

We are also organized into some… enterprise level specialty councils, particularly in our specialty practice. So, those are the groups that are really… using… most of the clinical evidence and developing protocols and the like. It is… the specialty councils who are responsible for creating those and using evidence from multiple sources… in order to generate those. They can be as simple as definitions and general approaches and then a way to contact the known experts…, or can be care process models that are very flowchart-oriented and tell you exactly what to do.

For some health-systems, especially the small and rural ones, most of the evidence is handled locally by the medical director or chief medical officer. They are responsible for identfying and vetting the literature and driving the process, sometimes with little to no resources. Involving a clinician champion in evidence-based practice review and development was cited as an important way to make change.

They are doing the discovery themselves and the sense of ownership appears to be driving a lot of improvement.

…it's getting harder and harder to dig up the evidence in the first place and do it one person at a time.

Using a mix of top down/bottom up approaches, especially to prioritize areas of improvement. Internal processes for prioritizing topics of interest to clinicians and health care managers were described in the interviews – some described as occuring at the individual clinician level and spreading organically, others with a more formal top-down structured approach beginning with health-system leadership. So while new literature evidence may be an impetus to assess a process, frequently health-systems identfiy the target areas for improvement and then search for literature in that area.

They have a process by which they go through an annual vetting process to identify key areas… we're trying to intersect more with the kind of strategic and performance improvement operations of the organization

The way it works is that we are hunting for evidence around a specific topic… if I could tell if I hit a live one, that would be handy, because it would speed me up.

You take a high priority process and you build an evidence-based practice around it.

Health-systems also use these approaches to prioritize competing issues. They understand that they cannot correct every discrepency at the same time.

We think these are the top five to eight things, as an organization, that either need dedicated or focused attention, that the entities, through their own planning, need to do.

In addition to describing the processes for getting and using evidence in the health-systems, KIs also noted some of the challenges with the current processes which included:

Integrating evidence and changes into clinical processes. Most of the KIs touched on the amount of work it takes to transform evidence from reviews or guidelines into practical clinical application. Some of the concerns included how to communicate the basis for process changes within the health-system and how to craft a change that minimizes the impact to workflow for practitioners.

The key to success is integrating into the workflow or developing a workflow that allows use of that evidence to occur.

His aim was to get the evidence in front of physicians… at the point in time they were making a clinical decision. … How do you get it right where it's needed at the moment it's needed, and in an easy to use format where people don't have to look it up?

When I look at it and when I start looking at the details, ‘well but how do you even operationalize something like this?’ … it will involve a lot more thought into the process of how do you operationalize something that's evidence-based and put it into your day-to-day practice.

In larger health-systems these changes require the approval of governing bodies before they can be implemented and then the front line clinicians need to be educated about the changes.

Our governance process involves an Executive Committee, the Care Redesign Oversight Committee, that includes hospital Presidents, the Chief Nursing Officer for the system, the Chief Medical Officer for the system, our Executive Vice President for the system, the VP from Performance Services, the CFO for our inpatient facilities, as well as other leaders. The leaders of our Care Redesign teams present their initial data--performance data as well as salient literature--to inform decisions about practice changes to that committee using a standard presentation format. The committee exists to support changes and to identify any resource needs or any potential competing priorities in a particular area.

We also have a template to communicate the basis for change and some of the evidence involved to inform those changes. We would typically deploy those materials at faculty meetings, nurse staff meetings, and in forums attended by the people who will need to change their day-to-day work as a result of the decisions by the Care Redesign Team.

## Sources and Formats of Evidence Used

KIs were asked about where they typically get their evidence from in terms of sources/producers of the evidence and which types of evidence they prefer. In addition, KIs were also asked about the typical format they like their systematic reviews to be presented in.

### Desired Sources of Evidence

Guidelines and systemtic reviews are highly sought after. All of the health-systems believe in and use evidence from the literature in quality, safety, and process improvement decisionmaking but most KIs felt that guidelines and systematic reviews were particularly valuable as a very efficient way to understand the topic area. KIs liked how systematic reviews include data synthesis as well as the raw evidence; and they rely primarily on the summary section of the reviews.

I really like guidelines, I really like systematic reviews, and part of that is because, you know, you're consolidating evidence, and oftentimes you're able to come up with more straightforward recommendations as a result of that.

I really like guidelines and systematic reviews; it's probably my first go-to.

I like simple reviews at a high level or a consensus paper and then to drill down and pull out references that were used to delvelop that consensus.

Guidelines and systematic reviews were specifically identified as being useful for reconciling discordant evidence from trials and studies.

I can find half a dozen articles that tell me that's a good idea to do it and half a dozen say it doesn't make a difference. Right? Like, that we have to make a determination of ‘is there evidence to support this or not’, and ‘is there any specific recommendation that would happen’… so in that sense, guidelines and systematic reviews are very helpful.

KIs felt that randomized controlled trials are specifically desired by clinical experts on health-system committees making quality, safety, or process improvements. One KI reported that clinical experts were skeptical of systematic reviews, arguing that their results were oversimplified, did not take the circumstances of individual patients into account, and may not reflect contemporary practice.

…meta-analysis frequently contain a potpourri of trials that may or may not necessarily be timely or relevant to what many of our doctor's feel to be contemporary practice. The meta-analysis does have some utility but as I'm sure you know to collect a dozen trials, to do a meta-analysis, some of those trials included may be five, six, seven, eight years older, and so they [don't have] the gravitas, again the word, that either a professional society guideline or a large randomized prospective study would hold.

However, KIs felt that for those who are not experts int the field, randomized controlled trials are less desirable than guidelines or systematic reviews because they can be confusing and taken out of context.

…people like guidelines. I think if you look—for example, our nursing group, we have a very active nursing practice group. They really like guidelines because it provides clear direction, and kind of outsource the work of vetting and kind of saying this evidence is the right run or this is the right direction.

Experience and reputation of producers of systematic reviews are important. The experience and reputation are the most important indicators a KI uses for whether a source will be trusted and used in decisionmaking. KIs consistently referred to having greater trust in established evidence sources like AHRQ and Cochrane. Peer hospitals and physicians are good sources of best practices and advice, but not necessarily of systematic reviews.

I mean, certainly you can tell when things are more specifically industry-sponsored. Those I always kind of take with a grain of salt.

I pretty consistently go to things like AHRQ, NPSF, IHI, Cochrane; those are the types of things I will tend to gravite towards to look for evidence.

Preference for evidence of comparative effectiveness rather than just efficacy. KIs felt that knowing the balance of efficacy and safety of active treatments, rather than just the efficacy or just the effects versus placebo, and understanding the applicability of the evidence is critical to decisionmaking.

A whole lot of the trial evidence is not useful for the questions that I'm asking. It shows me that a particular treatment is better than nothing, but if I've got four or five treatments, I nearly never believe they're all equivalent. I've got five that I know are better than nothing, they're efficacious—which one's best?

Preference for clinical recommendations and actionable information. KIs from all types of health-systems expressed a desire for prepackaged solutions. Guidelines with specific and actionable recommendations and systematic reviews that included recommendations for practice and not just clinical trial results. They spoke very favorably of guidelines that included clinical pathways with step-by-step instructions for managing patients with specific conditions. Algorithms were appreciated because it helps facilitate an understanding of the current process and how the new information may impact that in an easier to understand fashion. This is important in root cause analysis.

Then they go into root cause analysis, that is where education begins. They start reading the evidence and start pulling the evidence down.

### Desired Formats of Systematic Reviews

Systematic reviews need to have a brief summary as well as be comprehensive in the full report. KIs generally stated a preference for a short, digestable systematic review summary that allows the reader to decide if the report was “fit to the purpose” for an issue the organization was investigating and thus likely worth investing time on reading the full report. When asked about the usefullness of systematic reviews one KI found it daunting to get through a major review and pull out the main points.

…it would have been nice if I didn't have to spend the whole day to get to the information and distill it for other folks.

KIs want to push the summary, with links to the journal article or full report, to appropriate improvement team leads. One KI noted wanting the summary available quickly without requiring clicking on multiple links. Another noted that PowerPoint slides help distill a summary. Whether KI preferred a summary as a straight-up statement of findings with a fast link to the report or as a summary that provides the gist of the larger publication followed by some interpretation depended more perhaps on personal preferences rather than organizational size or class.

KIs also stated that the people deeply involved in developing practice changes needed to dive deeply into the full reports to fully understand the evidence and therefore, the availabiliy and comprehensiveness of the full report is still important.

Anybody who's actually building an evidence-based best practice guideline better read the whole article, obviously.

### Gaps in Evidence Used

To better understand gaps in health-systems existing processes and evidence sources, KIs were asked to describe these gaps and future needs. Some of the key gaps consisted of the following:

How to use evidence when guidance and information are unclear or evidence is insufficent? Most KIs were concerned about what to do when there was no clear guidance on how to translate the available evidence into practice. They were interested in the most reasonable actions, not necessarily a list of options, to use in patient care. Practical point-of-care algorithms were recommended, for example.

So I'm going to point again at the ASCCP [American Society for Coloposcopy and Cervical Pathology], which I think is amazing because you can Google it and because it—literally you can say, ‘Okay, where does my patient fit,’ plug them into the top and figure out where to go next. If there was an algorithm PDF version of the JNC 8, like ‘woman in her fifties with these co-morbidities start here’, that would make it way more accessible.

…when you get this result, here's what you need to do.

In addition, in systematic reviews where there is insufficient evidence or low strength of evidence for a number of treatments or approaches, it is not always apparent whether all of the options can be considered equally insufficient/low evidence or if there is a scenario where one looks to be preferred (even if there is a chance that future research might contradict the advice).

How to use evidence that is frequently not applicable to the typical patient or patient subset seen by the health-system? KIs were concerned about the extent to which the evidence in the literature is applicable to the patient populations seen in the health-system. For example, some noted that identifying and predicting the impact of interventions in high-risk patients with many medical comorbidities is difficult because they are not well studied.

…there may not be great evidence for what you're trying to do because there's local systems of care that are impacting the applicability of many of the things that are being done in that space.

How to use evidence from a systematic review that may be out of date? In systematic reviews with moderate to high strength of evidence findings, KIs understand the long rigorous approaches that the investigators need to undergo. However, they are concerned with the delay from completing the analyses to publishing the results and worry that in the intervening time between publication and the time the health-system is using the review that new trials or studies have come out. They also worried that old and irrelevant evidence might be included in the analyses so that a comparison of two approaches might be tainted by trials not using contemporary baseline therapy.

Things change all the time so that what we may have known two or three years ago may be different this time around.

### Topics Most Interested In

To better understand the issues that are of greatest interest to the health-systems interviewed, we asked KIs about which topics they were most interested in for their decisionmaking, such as prevention strategies, diagnostic strategies, treatment strategies, health policies, and specific clinical domains. Overall, the topics of interst to KIs varied depending on their expertise, role, and position within the health-system. While the topics suggested varied, some examples of potential topics included:

- Predictive analytics
  ○ How to identify and predict high-risk and potentially high-cost patients?
    That to me is where sort of the predictive kind of analytics come in and that to me is a big need, especially in a high-referral practice like this because we tend to get the patients [the high-risk and high-cost patients] —and I'm sure all other AMCs will tell you this too—we tend to get these patients and so how can we sort of assess these patients in a way that really helps us personalize their care from both an outcome perspective and a cost perspective.
  ○ How to use predictive analytics to understand how the system is functioning?
  ○ How to predict readmissions and mortality?
- High-value care
  ○ How to limit pharmaceutical use?
    I feel like the thing that I'm most struggling with from an evidence-based standpoint, is limiting pharmaceuticals to non-pharmaceutical treatment, or figuring out how to follow all the guidelines without having people on 20 drugs, and how to de-prescribe in an evidence-based way based on age or co-morbidities or drug interactions.
  ○ What are the opportunities to substitute less costly, but equally effective, pharmaceuticals for specific health conditions?
    Can we substitute nicardipine which is relatively cheap as a vasodilator drug for nitroprusside which has increased tenfold in price over the past two years and we've had to sort of do the amalgamation. Have we—are we able to substitute Aggrastat for Integrilin, which the evidence show, if you will, equivalents for that.
    IV acetaminophen, perfect example that we're now having lots of controversy within our organization and we've had to do a big internal review of that because there is no real amalgamated opinion on the use of IV acetaminophen as a perioperative modulator of pain. So, if that type of service was available that might provide some value, if you will, on-demand data collection and amalgamation.
  ○ How to identify which diagnostic strategies related to imaging are most cost effective?
  ○ How to eliminate unneccessary laboratory testing?
- Advanced care planning
  ○ How to coordinate advanced care planning between the hospital, home care, hospice, primary care and specialty groups?
    So, we're trying to do work around advanced care planning and if you're really only focused on the hospital side of things, you're really not capturing—so how are we intersecting with our home care and hospice agencies? How are we intersecting with our primary care groups or specialty groups around advanced care planning? How are we creating access? So, it really behooves us to have a cross-continuum approach that we can't do at individual entities coming together to talk like a system. You have to actually function as a system to do some of that activity.
- Care transitions and coordinating care
  ○ How to improve handoffs across care settings?
  ○ How to coordinate advanced care planning between the hospital, home care, hospice, primary care and specialty groups?
- Some other topics that were briefly referenced include:
  ○ Measures health-systems are held accountable for (e.g., CMS measures, pay for value)
  ○ Antibiotic stewardship and use of antibiotic impregnated patches for pacemakers
  ○ Urinary tract infections
  ○ Falls
  ○ DVT prophylaxis
  ○ Second line infections
  ○ Selection of chemotherapy
  ○ Advanced heart failure procedures
  ○ Selecting the right patient for ECMO and other treatment strategies
  ○ Medication reconcilliation
  ○ Workforce resilience and well being
  ○ Developing relevant quality measures
  ○ Hepatitis C treatment coverage

### Familiarity With the AHRQ EPC Program and Impressions of EPC Reports

Although our interviews focused on how health-systems get and use evidence more broadly, we also wanted to explore their familiarity with existing EPC reports and how these might be modified to help them with their decisionmaking in the future

Lack of familiarity with AHRQ EPC reports. Among the nine KIs, two were very familiar with EPC reports and AHRQ and two others had used EPC reports or their derivative publications in journals in the past. One of these KIs attributed his familiarity with earlier work he conducted with AHRQ, and a second through regular emails received from AHRQ that include results from newly completed systematic reviews. A third KI was familiar with or had used AHRQ reports but was unfamiliar with the EPC program. The fourth KI reported having used Cochrane and AHRQ reports, but did not refer to them by name as EPC reports.

I'm familiar with the stuff that I receive from AHRQ because I do receive emails and I open them up once in a while and say, "Oh, this is pretty cool" but when I look at it and when I start looking at the details, "Well but how do you even operationalize something like this?"

I can go to… the Effective Health Care site. I've been on that but I've never really kind of connected it back to the EPC work in particular, thinking through how that happened, so that's really interesting.

Effective Health Care Web site not well known. Most KIs were not aware of the Effective Healthcare website and the ability to search using key terms. One KI noted that while email alerts are fine, it likely will not come out at exactly the time a process change is being considered. They really want to be able to access the information on-demand when they need it.

But the reality is, and using your example, if that review came out tomorrow and it sort of showed up in my inbox, I'd probably say, gee, that's very nice. It's not on our radar screen at the moment. So, that's why I spoke about having some ability to access that type of information really on demand or as needed because we're focusing on our current problems that may be driven by either we have a quality problem that needs to be addressed and it's fairly important, or we have a care delivery process that is being redesigned that we have to address, or we are faced with an important financial decision

The reports are helpful when discovered by health-systems. Four of the KIs said that they found the reports useful. One commented that they used a report when they could not find information elsewhere. Because the reports can be difficult to read, they start with more distilled information, like a journal article and then go to the larger report if they need more detail. Another said that the reports provide a baseline of what is known and not known.

One of the places that actually had it was AHRQ and I looked at the evidence and I was able to forward it to the provider that I needed to forward it to and I actually did make a presentation out of it as well.

Email notifications about reports should include brief summaries. When asked about what would be the best way for AHRQ to alert health-systems to reports on these topics, KIs noted that email is often the best way. However, KIs noted they wanted a brief summary of the topic in the email so they could easily determine whether it was relevant – and whether they should click on the link for more information. Some suggested models that use this approach including Journal Watch, Prescriber's letter, and Annals of Internal Medicine.

… my Journal Watch subscription… also helps you, like I said, to sort of gauge when evidence is changing around a topic and you might need to adjust practice. So, there are a couple of things about that that I like. It keeps evidence and evidence-based practice right front and center as I am providing care. It's something I think about every day. It comes as a really digestible synopsis format that I can skim while I'm drinking coffee, going to the bathroom, whatever. It's super easy, and it has links to full articles…

I'll give an example of something that might work better is when Annals sends communications that are a little bit shorter and has the gist of what's in the bigger content, then that probably helps a lot more than just providing a link of the title and then saying that, ‘Go to this link to see more of it’ but when you click on the link it's like two or three pages long.

Alerts at multiple levels in an organization is the best strategy. In terms of who to notify about new reports released, KIs noted that there would likely be a number of people within a health-system who should be notified, including the interviewees themselves, medical directors, chief medical directors, quality and safety officers, clinical development teams, and teams working on the specific issues. This increases the chances that it will be seen by someone actively working in that area at the time.

Remember that the way it works is, we don't just come and search the list just looking for something interesting, that's not how it works. The way it works is that we are hunting for evidence around a specific topic.

Some health-systems would be interested in a closer partnership with the EPC program. KIs from some of the health-systems saw the potential for a closer partnership with AHRQ's EPC Program where they could recommend topics critical to their needs and have members of the health-systems serve as Key Informants for future Workgroups to identify key questions pertinent to health-systems.

…the idea that we could help set their agenda. That's a great idea. Because, we know what the big topics are, typically. We can say, “These are the things that are that combination of key processes, plus the things that are getting really heavy focus from the Feds.”

The length of time from conception to EPC report publication inhibits maximum impact. Health-systems go from issue identification or metric discrepancy to fashioning process changes in a few months. Waiting a year from idea conception to having the results in a report impedes the rapid progress health-systems desire.

I wonder if we could better interconnect those. Now, the only real difficulty I anticipate, believe it or not, is that you won't be able to respond quickly enough…

When asked how long their timeline is from starting to work on a topic to process changes being proposed, one KI responded.

You're going to hate this. A maximum of three months.

However, the KI pointed out that although health-systems need to take action quickly, there are several opportunities for impacting downstream updates with an evidence report which might not be ready for the initial process change. Specifically, after rolling out process changes in a health-system, there are issues when it is implemented and modifications are often made several months down the line. In addition, there are also scheduled updates where new evidence can inform revisions.

I don't get it on the first pass, but by the time we come around to the next cycle--my teams meet monthly and they review these protocols monthly, their own experience, people suggest changes to the frontline, new evidence. So, it's not like they're static. A good one is… in a constant state of update to reflect current best knowledge, best experience.