# Discussion and Limitations

This is one of the few known projects of its kind that specifically identifies the process and role of evidence in quality, safety, and process improvements within health-systems. We asked leaders in the field who represented or had knowledge of what was happening in academic, nonacademic, and small and rural health-systems so that we would better understand their evidence needs. Based on the feedback we received, we proposed seven recommendations that can help AHRQ's EPC program have greater visibility and impact in health-systems. The insight we gained and the recommendations we propose are, by and large, in line with those derived from prior literature as well.

Our first, second, and third recommendations center around making it easier for people in health-systems to access our reports, rapidly discern if the results are relevant to them, and to enhance the readability and clarity of those reports. These findings are similar to those of Academy Health who spearheaded semi-structured interviews with 43 individuals from safety-net health-systems in 2016.^4^ The individuals from the Academy Health study encouraged researchers to learn to speak and write using clear language that is meaningful to clinicians, health-system executives, and others while tailoring a publication's length and level of detail to the needs of the intended audience. Several KIs pointed to the usefulness of one-page research briefs or syntheses that describe the problem being examined, the intervention tested, and the outcomes, with links or citations that direct the reader to more information.

Our sixth recommendation centers around educating health-systems that there is a topic nomination process where topics of particular importance to health-systems can be made and around having AHRQ partner more closely with some health-systems like they do with professional organizations and federal agencies. In the Academy Health project, health-system KIs emphasized that they have evidence needs that are unique to them and not currently assessed. KIs in the Academy Health study wanted evidence on interventions that enhance coordination and transitions of care, data sharing efficiency intra- and inter-institutionally (health-systems, pharmacies, long-term care, visiting nurses), and effectiveness of various community based interventions in patients with health disparities.^4^ This is very similar to topics identified in our current project where predictive analytics, advanced care planning, care transitions, and coordination of care are specifically called out. Tying health-systems into topic nomination and partnering with them to identify and prioritize topics with particular importance to health-systems can better assure that we create reports with greater impact.

Our seventh recommendation centers around enhancing the awareness of AHRQ's EPC Program which is critical to the success of the other recommendations. In an assessment of formulary decisionmakers in health-systems published in 2013, 39 pharmacists and 18 physicians on health-systems pharmacy & therapeutics committees participated in 90-minute focus groups.^5^ Overall, 51% of KIs said they had heard of the site to access EPC reports and 28% had used material from them. This is very similar to what we found in our current project with four of nine KIs being familiar with EPC reports and/or the journal publications that result from them.

Our fourth and fifth recommendations are to consider ways to reduce the time from starting a systematic review to the publication of the report and working to make the results as actionable as possible. In the formulary decisionmaker project, guidelines and clinical trials were the most highly sought after type of evidence with systematic reviews coming in third. The main critiques of EPC reports in the formulary decisionmaker project that limited their effectiveness were: the reports lacked timeliness (they came out months after the new drug needed to be reviewed internally), and the results were perceived as largely inconclusive.^5^ In our current project, KIs feel the timeframe from project initiation until publication of a systematic review is too long and they prefer guidelines because they have more definitive recommendations. Systematic reviews cannot be guidelines, even though quality guidelines are driven by rigorous systematic reviews. However, they can be written clearly with the step in the care process being investigated elucidated to facilitate action within the health-system.

Our report should be viewed in light of a companion report entitled “Developing a Framework for Evidence Needs of Health-Systems” which was created in tandem by other representatives from the EPCs and AHRQ. While we enhanced our understanding of evidence needs for quality, safety, and process improvement through interviews with representatives from health-systems in our report, the companion report comprehensively summarizes what has already been published on this topic. Their recommendations are very much in line with ours, centering around alerting people in health-systems to new systematic review reports in a tiered manner with less detail initially, reducing the timeline from starting a project to generating a systematic review report, and partnering more closely with health-systems in topic nomination, prioritization, and development.

Our report describes the perceptions of, and recommendations from, health-system representatives who participated in our quality improvement project. The main limitation is that we did not query a large number of health-systems, just a small sample. In addition, we scheduled each of the interviews for hour-long blocks, limiting the amount of feedback we could receive versus using longer interview periods. Even with these limitations, we believe that the feedback is largely consistent across the KIs providing greater confidence in the applicability of the findings.