# Conclusion

There are difference between large and small health-systems in terms of the personnel who lead quality, safety, and process changes, access to internal data and literature evidence, and the sophistication of the support team. Guidelines, systematic reviews, and randomized controlled trials were all highly sought after sources of evidence. The ability to summarize large amounts of evidence efficiently within a guideline or systematic review and the ability to reconcile conflicting trials is valuable, especially for nonspecialists. Systematic reviews, however, can be difficult for health-systems to identify, access, and utilize. In addition, there are topics unique to health-systems that could be explored by EPCs but currently are not. We propose recommendations that could enhance knowledge of the EPC program and the utilization and impact of EPC reports. Improving how we alert people in health-systems about new reports, making reports more clear and concise, and reaching out to members of health-systems to nominate topics and to partner more closely with us could result from adoption of these recommendations.