# Background

In its report Best Care at Lower Cost: The Path to Continuously Learning Health Care in America, the Health and Medicine Division of the National Academy of Sciences proposes ways the health care system can promote continuous learning and improve health quality, outcomes, cost, and equity.^1^ To be a learning health care system, health care systems should have real-time access to knowledge, digital capture of the care experience, engaged and empowered patients, leadership-instilled culture of learning, incentives linked to value, and supportive system competencies.^2,3^ The access to and usability of high quality evidence is a linchpin for making quality, safety, process, or purchasing decisions. In response to the NAS's call to promote learning health care systems,^1^ the Agency for Healthcare Research and Quality (AHRQ) is exploring how its work can facilitate these changes and improvements.

AHRQ's Evidence-based Practice Center (EPC) program funds independent EPCs across the United States and Canada to conduct rigorous and comprehensive evidence reviews of scientific literature. These reviews focus on a variety of issues, including assessing and comparing clinical drugs, treatments, interventions, and diagnostic tests to improve health care delivery. The EPC program's reports are used regularly by guideline groups, professional societies, and policy-makers. However, it is unclear how health-systems access and use evidence and how the EPC Program could make its reports more useful to health-systems.