# Appendix A Script for Quality, Safety and Process Leaders Interviews

Thank you for agreeing to meet with us today, we really appreciate your time and hope to get a better understanding about your organization and how decisionmakers within your health-system use evidence in making important care decisions.

As some background -- the Agency for Healthcare Research and Quality (AHRQ) is the lead Federal agency within the U.S. Department of Health and Human Services that is charged with improving the quality, safety, efficiency, and effectiveness of health care for all Americans. One of its programs, the Evidence-based Practice Center (EPC) program, funds 13 independent EPCs across the United States and Canada to conduct rigorous, comprehensive evidence reviews of scientific literature. These reviews focus on a variety of issues, including comparing clinical drugs or treatments, and interventions to improve health care delivery. We are conducting this project because we know our EPC work is being used by people such as guideline groups and major payors but we don't know the extent to which it is being used by key decisionmakers in health-systems. If we understood more about health-systems and the major decisionmakers who could benefit from evidence reviews, we may be able to partner more effectively with them, produce more useful products for use in this setting, let them know about our reviews, and make our future projects responsive to the needs of health-system decisionmakers.

- Do you have any questions about the overall purpose of this project?
- We would like to record the session so that we can be sure that we capture your thoughts and insight accurately. Would this be ok?

Before we dive in to our questions about using evidence within your health-system we just need a little more information on your specific role and the structure of your health-system:

1. What is your current title/role within your institution?
2. Can you tell me about how you fit into your health-system? What other departments do you interact with most? Can you describe broadly how your health-system is currently structured? {Prompts, top down structure impacted whole system or confederation of independent parts}

We now want to ask you specifically about the use of evidence within your health-system – both in terms of your use of evidence and where there are gaps that could be filled.

## Process for Reviewing and Using Evidence

1. At your health-system (and within your role) what is the current process for reviewing and using evidence?
2. Who within your health-system makes the decisions about what to do with the evidence? What departments/divisions do these decisions apply to? You can think broadly about allied health professionals such as nursing and pharmacy.
3. In the next 5 years, how do you anticipate decisionmaking to change at your health-system? E.g., will it be made in a more centralized manner? More decentralized? Or on the basis of external guidelines?
4. What do you see as the greatest barriers to evidence-based medicine in your health-system?

## Sources of Evidence

5 What sources do you most frequently use for identifying evidence? For reviewing evidence?
6 Who produces this evidence?
7 E.g., information that comes from within the health-system? Cochrane? AHRQ? Other sources?

## Format of Evidence

8 When you review evidence, typically what format is it in? E.g., formal report, memo, PowerPoint, etc?
9 What is the typical length of this format?
10 What format do you normally use to disseminate evidence to your health-system members?

## Gaps in Evidence Used

11 Do you see gaps in how you currently get evidence? How would you like to get evidence?

## Topics Most Interested In

12 What topics are you most interested in for your decisionmaking?
  ○ Prevention strategies
  ○ Diagnostic strategies
  ○ Treatment strategies
    ▪ Drugs, devices, non-pharmaceuticals…
  ○ Health policies
  ○ Specific clinical domains?
13 If we had AHRQ EPC reports that assessed any of these topics, how would you feel about AHRQ alerting you when they became available?
  - ○ What is the best way to alert you?

## Familiarity With AHRQ EPC program

14 Are you familiar with the AHRQ EPC reports?
  ○ If yes:
    ▪ Are there specific reports that you have found useful in your past decisionmaking?
    ▪ Are there things that you have found not useful about the EPC reports?

## Other

15 Is there anything else that you feel would be helpful for AHRQ and the EPCs to know about your evidence needs and how they can better meet your evidence needs?
16 Would you be willing to share any exemplars/examples of evidence that you use?

That is all of our questions for today. Thank you for your time. We are going to be talking to some other decisionmakers from your institution and from other health-systems. This information will be very helpful to AHRQ and the EPC Program as we consider next steps.