# References

1 Higgins JP, Green S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. The Cochrane Collaboration. 2011. http://handbook.cochrane.org/. 2016 Mar 24.
2 Committee on Standards for Systematic Reviews, Institute of Medicine, Eden J, Levit L, Berg A, et al., editors. Finding what works in health care: standards for systematic reviews. Washington (DC). National Academies Press. 2011. Mar. 23.
3 Hartling L, Guise JM, Kato E, et al. EPC methods: An exploration of methods and context for the production of rapid reviews. Research White Paper. (Prepared by the Scientific Resource Center under Contract No. 290-2012-00004-C.) AHRQ Publication No. 15-EHC008-EF. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2015. Feb.
4 Hempel S, Shetty KD, Shekelle PG, et al. Machine learning methods in systematic reviews: identifying quality improvement intervention evaluations. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-2007-10062-I). Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2012. Sep. 55 p.
5 Dalal SR, Shekelle PG, Hempel S, et al. A pilot study using machine learning and domain knowledge to facilitate comparative effectiveness review updating. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-2007-10062-I). Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2012. Sep. 50 p.
6 Thomas J, McNaught J, Ananiadou S. Applications of text mining within systematic reviews. Res Synth Meth. Mar. 2011;2(1):1-14. [pmid: 26061596].
7 Miner G, Elder J IV, Hill T, et al. Practical text mining and statistical analysis for non-structured text data applications. Waltham (MA). Elsevier Inc. 2012. Jan. 25. 1000 p.
8 Methods guide for effectiveness and comparative effectiveness reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2014. Jan.
9 Campbell Collaboration. Campbell Collaboration Systematic Reviews: policies and guidelines. Version 1.1. Norway. Campbell Collaboration. 2015. Jan. 14. 47 p. (Campbell Systematic Reviews, Supplement 1).
10 Evidence for Policy and Practice Information and Co-ordinating Centre. EPPI-Centre Methods for Conducting Systematic Reviews. London (UK). Social Science Research Unit, Institute of Education, University of London. 2010.
11 Joanna Briggs Institute. Joanna Briggs Institute reviewer's manual: 2014 edition. Adelaide, South Australia. The Joanna Briggs Institute. 2014. 197 p.
12 European Network for Health Technology Assessment. EUnetHTA Joint Action 2, Work Package 8. HTA Core Model® version 2.1. European Network Health Technology Assessment. 2015. [453 p]. http://www.corehta.info/BrowseModel.aspx. 2015 Aug 04.
13 European Network for Health Technology Assessment. Process of information retrieval for systematic reviews and health technology assessments on clinical effectiveness. Copenhagen (Denmark). European Network for Health Technology Assessment. 2015. Jul. 70 p.
14 O'Mara-Eves A, Thomas J, McNaught J, et al. Using text mining for study identification in systematic reviews: a systematic review of current approaches. Syst Rev. 2015;4:5. [pmid: 25588314].
15 Jonnalagadda SR, Goyal P, Huffman MD. Automating data extraction in systematic reviews: a systematic review. Syst Rev. Jun. 15. 2015;4(1):78. [pmid: 26073888].
16 Fleuren WW, Alkema W. Application of text mining in the biomedical domain. Methods. Mar. 2015;74:97-106. [pmid: 25641519].
17 Charmaz K. Reconstructing grounded theory. Alasuutari P, Bickman L, Brannen J, editors. SAGE handbook of social research methods. London. Sage. 2008:461-79.
18 OBrien BC, Harris IB, Beckman TJ, et al. Standards for reporting qualitative research: a synthesis of recommendations. Acad Med. Sep. 2014;89(9):1245-51. [pmid: 24979285].
19 Saldana J. Descriptive coding. Saldana J, editor. The coding manual for qualitative researchers. Thousand Oaks (CA). Sage. 2013:87-91.
20 Taylor B. Grounded theory. Taylor BJ, Francis K, editors. Qualitative research in the health sciences: methodologies, methods, and processes. New York. Routledge. 2013:30-55.
21 Qualitative Solutions and Research (QSR). NVivo 10 for Windows: qualitative data analysis software. Melbourne (Australia). QSR International. 2015. http://www.qsrinternational.com/products_nvivo.aspx. 2015 Aug 12.
22 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate healthcare interventions: explanation and elaboration. BMJ. 2009;339:b2700. [pmid: 19622552].
23 Calders T, Esposito F, Hullermeier E, et al. Machine learning and knowledge discovery in databases. Proceedings, Part III. Springer Heidelberg, New York, Dordrecht, London. European Conference, ECML PKDD 2014. September 15-19, 2014. Nancy, France. 2014.
24 Felizardo KR, Nakagawa EY, Feitosa D, et al. An approach based on visual text mining to support categorization and classification in the systematic mapping. Proceedings of the 14th international conference on Evaluation and Assessment in Software Engineering (EASE'10); British Computer Society. Swinton (UK). 2010:34-43.
25 Felizardo KR, Macdonell SG, Mendes E, et al. A systematic mapping on the use of visual data mining to support the conduct of systematic literature reviews. J Software. 2012;7(2):450-61.
26 Hotho A, Nurnberger A, Paaß G. A brief survey of text mining. 2005. May. 13.
27 Kao A, Poteet SR, editors. Natural language processing and text mining. London (UK). Springer-Verlag. 2007.
28 Sizov G. Extraction-based automatic summarization. Theoretical and empirical investigation of summarization techniques. Norwegian University of Science and Technology. 2010. Jan.
29 Zhang Q, Segall R. Review of data, text and web mining software. Kybernetes. 2010;39(4):625-55.
30 Hausner E, Waffenschmidt S, Kaiser T, et al. Routine development of objectively derived search strategies. Syst Rev. 2012;1:19. [pmid: 22587829].
31 O'Mara-Eves A, Brunton G, McDaid D, et al. Techniques for identifying cross-disciplinary and ‘hard-to-detect’ evidence for systematic review. Res Synth Meth. Mar. 2014;5(1):50-9. [pmid: 26054025].
32 Simon M, Hausner E, Klaus SF, et al. Identifying nurse staffing research in Medline: development and testing of empirically derived search strategies with the PubMed interface. BMC Med Res Methodol. 2010;10:76. [pmid: 20731858].
33 Tanon AA, Champagne F, Contandriopoulos AP, et al. Patient safety and systematic reviews: finding papers indexed in MEDLINE, EMBASE and CINAHL. Qual Saf Health Care. Oct. 2010;19(5):452-61. [pmid: 20457733].
34 Balan PF, Gerits A, Vanduffel W. A practical application of text mining to literature on cognitive rehabilitation and enhancement through neurostimulation. Front Syst Neurosci. 2014;8:182. [pmid: 25309356].
35 Kok R, Verbeek JA, Faber B, et al. A search strategy to identify studies on the prognosis of work disability: a diagnostic test framework. BMJ Open. 2015;5(5):e006315. [pmid: 25991444].
36 Petrova M, Sutcliffe P, Fulford KW, et al. Search terms and a validated brief search filter to retrieve publications on health-related values in Medline: a word frequency analysis study. J Am Med Inform Assoc. 2012;19(3):479-88. [pmid: 21846778].
37 Damarell RA, Tieman J, Sladek RM, et al. Development of a heart failure filter for Medline: an objective approach using evidence-based clinical practice guidelines as an alternative to hand searching. BMC Med Res Methodol. 2011;11:12. [pmid: 21272371].
38 Li J, Lu Z. Developing topic-specific search filters for PubMed with click-through data. Methods Inf Med. 2013;52(5):395-402. [pmid: 23666447].
39 Iansavichus AV, Hilderbrand AM, Haynes RB, et al. High performance information search filters for CKD content in PubMed, Ovid MEDLINE, and EMBASE. Am J Kidney Dis. 2015;65(1):26-32. [pmid: 25059221].
40 Shemilt I, Simon A, Hollands GJ, et al. Pinpointing needles in giant haystacks: use of text mining to reduce impractical screening workload in extremely large scoping reviews. Res Synth Meth. Mar. 2014;5(1):31-49. [pmid: 26054024].
41 Thompson J, Davis J, Mazerolle L. A systematic method for search term selection in systematic reviews. Res Synth Meth. 2014;5(2):87-97.
42 Slater L. Product review: PubMed PubReMiner. J Canadian Health Libr Assoc. 2012;33(2):106-7.
43 Poultor GL, Rubin DL, Altman RB, et al. MScanner: a classifier for retrieving Medline citations. BMC Bioinformatics. 2008;9:108. [pmid: 18284683].
44 Macdonald EM, Carroll A, Albiston D, et al. Social relationships in early psychosis: clinical data-mining for practice-based evidence. J Soc Work Res Eval. Fall-Winter. 2005;6(2):155-66.
45 Choong MK, Galgani F, Dunn AG, et al. Automatic evidence retrieval for systematic reviews. J Med Internet Res. 2014;16(10):e223. [pmid: 25274020].
46 Hausner E, Guddat C, Hermanns T, et al. Development of search strategies for systematic reviews: validation showed the noninferiority of the objective approach. J Clin Epidemiol. Feb. 2015;68(2):191-9. [pmid: 25464826].
47 Franzi K, Ananiadou S, Mima H. Automatic recognition of multi-word terms: the C-value/NC-value method. Int J Digit Libr. 2000;3(2):115-30.
48 Powers DM. Evaluation: from precision, recall and F-factor to ROC, informedness, markedness & correlation. Adelaide (South Australia). Flinders University of South Australia. 2007. Dec. 24 p. (Technical report; no.SIE-07-001).
49 Wallace BC, Trikalinos TA, Lau J, et al. Semi-automated screening of biomedical citations for systematic reviews. BMC Bioinformatics. 2010;11:55. [pmid: 20102628].
50 Wallace BC, Small K, Brodley CE, et al. Modeling annotation time to reduce workload in comparative effectiveness reviews. Conference Proceedings. 1st ACM International Health Informatics Symposium, IHI '10. November 11-12, 2010. 28-35.
51 Wallace BC, Small K, Brodley CE, et al. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the ACM International Health Informatics Symposium (IHI). 2012:819-24.
52 Rathbone J, Hoffmann T, Glasziou P. Faster title and abstract screening? Evaluating Abstrackr, a semi-automated online screening program for systematic reviewers. Syst Rev. 2015;4:80. Also available: http://dx.doi.org/10.1186/s13643-015-0067-6. [pmid: 26073974].
53 Marshall IJ, Kuiper J, Wallace BC. RobotReviewer: evaluation of a system for automatically assessing bias in clinical trials. J Am Med Inform Assoc. 2015. Jun. 22. Epub ahead of print. [pmid: 26104742].
54 Hsu W, Speier W, Taira RK. Automated extraction of reported statistical analyses: towards a logical representation of clinical trial literature. AMIA Annu Symp Proc. 2012:350-9. [pmid: 23304305].
55 Shao W, Adams CE, Cohen AM, et al. Aggregator: a machine learning approach to identifying MEDLINE articles that derive from the same underlying clinical trial. Methods. Mar. 1. 2015;74:65-70. [pmid: 25461812].
56 Cohen AM, Smalheiser NR, McDonagh MS, et al. Automated confidence ranked classification of randomized controlled trial articles: an aid to evidence-based medicine. J Am Med Inform Assoc. May. 2015;22(3):707-17. [pmid: 25656516].
57 Cohen AM, Ambert K, McDonagh M. Studying the potential impact of automated document classification on scheduling a systematic review update. BMC Med Inform Decis Mak. Apr. 19. 2012;12(1):33. [pmid: 22515596].
58 Cohen AM. Optimizing feature representation for automated systematic review work prioritization. AMIA Annu Symp Proc. 2008:121-5. [pmid: 18998798].
59 Dalal SR, Shekelle PG, Hempel S, et al. A pilot study using machine learning and domain knowledge to facilitate comparative effectiveness review updating. Med Decis Making. 2013;33(3):343-55. [pmid: 22961102].
60 Cunningham H, Tablan V, Roberts A, et al. Getting more out of biomedical documents with GATE's full lifecycle open source text analytics. PLoS Comput Biol. 2013;9(2):e1002854. [pmid: 23408875].
61 Turner MD, Chakrabarti C, Jones TB, et al. Automated annotation of functional imaging experiments via multi-label classification. Front Neurosci. 2013;7:240. [pmid: 24409112].
62 Williams SA, Porter V, Zarotsky V, et al. An evaluation of literature on discontinuation rates of biologics in rheumatoid arthritis [abstract]. Arthritis Rheum. Oct. 2012;64(S10):483.
63 McKenzie K, Scott DA, Campbell MA, et al. The use of narrative text for injury surveillance research: a systematic review. Accid Anal Prev. Mar. 2010;42(2):354-63. [pmid: 20159054].
64 Smalheiser NR, Zhou W, Torvik VI. Anne O'Tate: A tool to support user-driven summarization, drill-down and browsing of PubMed search results. J Biomed Discov Collab. 2008;3:2. [pmid: 18279519].
65 Wojtusiak J, Michalski RS, Simanivanh T, et al. Towards application of rule learning to the meta-analysis of clinical data: an example of the metabolic syndrome. Int J Med Inform. 2009;78(12):e104-e111. [pmid: 19464941].
66 Fontelo P, Liu F, Ackerman M. askMEDLINE: a free-text, natural language query tool for MEDLINE/PubMed. BMC Med Inform Decis Mak. 2005;5:5. [pmid: 15760470].
67 Kossenkov A, Manion FJ, Korotkov E, et al. ASAP: automated sequence annotation pipeline for web-based updating of sequence information with a local dynamic database. Bioinformatics. Mar. 22. 2003;19(5):675-6. [pmid: 12651736].
68 Divoli A, Attwood TK. BioIE: extracting informative sentences from the biomedical literature. Bioinformatics. May. 1. 2005;21(9):2138-9. [pmid: 15691860].
69 Papanikolaou N, Pavlopoulos GA, Pafilis E, et al. BioTextQuest(+): a knowledge integration platform for literature mining and concept discovery. Bioinformatics. Nov. 15. 2014;30(22):3249-56. [pmid: 25100685].
70 Ananiadou S, Rea B, Okazaki N, et al. Supporting systematic reviews using text mining. Soc Sci Comput Rev. Nov. 2009;27(4):509-23.
71 Chen H, Sharp BM. Content-rich biological network constructed by mining PubMed abstracts. BMC Bioinformatics. Oct. 8. 2004;5:147. [pmid: 15473905].
72 Fleuren WW, Verhoeven S, Frijters R, et al. CoPub update: CoPub 5.0 a text mining system to answer biological questions. Nucleic Acids Res. Jul. 2011;39(Web Server issue):W450-4. [pmid: 21622961].
73 Yamamoto Y, Yamaguchi A, Yonezawa A. Building linked open data towards integration of biomedical scientific literature with DBpedia. J Biomed Semantics. 2013;4(1):8. [pmid: 23497538].
74 Errami M, Wren JD, Hicks JM, et al. eTBLAST: a web server to identify expert reviewers, appropriate journals and similar publications. Nucleic Acids Res. Jul. 2007;35(Web Server issue):W12-5. [pmid: 17452348].
75 Kiritchenko S, de Bruijn B, Carini S, et al. ExaCT: automatic extraction of clinical trial characteristics from journal publications. BMC Med Inform Decis Mak. 2010;10:56. [pmid: 20920176].
76 Tsuruoka Y, Tsujii J, Ananiadou S. FACTA: a text search engine for finding associated biomedical concept. Bioinformatics. Nov. 1. 2008;24(21):2559-60. [pmid: 18772154].
77 Yu W, Clyne M, Dolan SM, et al. GAPscreener: an automatic tool for screening human genetic association literature in PubMed using the support vector machine technique. BMC Bioinformatics. 2008;9:205. [pmid: 18430222].
78 Marshall C, Brereton P. Tools to support systematic literature reviews in software engineering: a mapping study. Conference Proceedings. 2013 ACM/IEEE International Symposium on Empirical Software Engineering and Measurement. October 10, 2013. 296-9.
79 Doms A, Schroeder M. Go exploring PubMed with the Gene Ontology. Nucleic Acids Res. Jul. 1. 2005;33(Web Server issue):W783-6. [pmid: 15980585].
80 Seo J, Shneiderman B. Knowledge discovery in high-dimensional data: case studies and a user survey for the rank-by-feature framework. IEEE Trans Vis Comput Graph. May-Jun. 2006;12(3):311-22. [pmid: 16640245].
81 Eaton AD. HubMed: a web-based biomedical literature search interface. Nucleic Acids Res. Jul. 1. 2006;34(Web Server issue):W745-7. [pmid: 16845111].
82 Giglia E. Quertle and KNALIJ: searching PubMed has never been so easy and effective. Eur J Phys Rehabil Med. Dec. 2011;47(4):687-90. [pmid: 22222966].
83 Stansfield C, Thomas J, Kavanagh J. ‘Clustering’ documents automatically to support scoping reviews of research: a case study. Res Synth Meth. Sep. 2013;4(3):230-41. [pmid: 26053843].
84 Lin JW, Chang CH, Lin MW, et al. Automating the process of critical appraisal and assessing the strength of evidence with information extraction technology. J Eval Clin Pract. Aug. 2011;17(4):832-8. [pmid: 21707873].
85 Sarkar IN, Schenk R, Miller H, et al. LigerCat: using “MeSH Clouds” from journal, article, or gene citations to facilitate the identification of relevant biomedical literature. AMIA Annu Symp Proc. 2009;2009:563-7. [pmid: 20351918].
86 Fontaine JF, Barbosa-Silva A, Schaefer M, et al. MedlineRanker: flexible ranking of biomedical literature. Nucleic Acids Res. Jul. 2009;37(Web Server issue):W141-6. [pmid: 19429696].
87 Theodosiou T, Vizirianakis IS, Angelis L, et al. MeSHy: mining unanticipated PubMed information using frequencies of occurrences and concurrences of MeSH terms. J Biomed Inform. 2011;44(6):919-26. [pmid: 21684350].
88 Aronson AR, Lang FM. An overview of MetaMap: historical perspective and recent advances. J Am Med Inform Assoc. May-Jun. 2010;17(3):229-36. [pmid: 20442139].
89 Tenner H, Thurmayr G, Thurmayr R. Data mining with Meva in MEDLINE. Perner P, Brause R, Holzhutter HG, editors. Medical data analysis. Springer Berlin. Heidelberg. 2003;2868:39-46.
90 States DJ, Ade AS, Wright ZC, et al. MiSearch adaptive pubMed search tool. Bioinformatics. Apr. 1. 2009;25(7):974-6. [pmid: 18326507].
91 Salgado D, Krallinger M, Depaule M, et al. MyMiner: a web application for computer-assisted biocuration and text annotation. Bioinformatics. Sep. 1. 2012;28(17):2285-7. [pmid: 22789588].
92 Aronson AR, Mork JG, Gay CW, et al. The NLM Indexing Initiative's Medical Text Indexer. Stud Health Technol Inform. 2004;107(Pt 1):268-72. [pmid: 15360816].
93 Castleberry A. NVivo 10 [software program]. Version 10. QSR International; 2012. Am J Pharm Educ. Feb. 12. 2014;78(1):25.
94 Cohen AM, Hersh WR, Peterson K, et al. Reducing workload in systematic review preparation using automated citation classification. J Am Med Inform Assoc. Mar-Apr. 2006;13(2):206-19. [pmid: 16357352].
95 Raja K, Subramani S, Natarajan J. PPInterFinder--a mining tool for extracting causal relations on human proteins from literature. Database (Oxford). 2013;2013:bas052. [pmid: 23325628].
96 Malheiros V, Hohn E, Pinho R, et al. A visual text mining approach for systematic reviews. Conference Proceedings. 2007 First International Symposium on Empirical Software Engineering and Measurement. September 20, 2007. 245-54.
97 Plikus MV, Zhang Z, Chuong CM. PubFocus: semantic MEDLINE/PubMed citations analytics through integration of controlled biomedical dictionaries and ranking algorithm. BMC Bioinformatics. 2006;7:424. [pmid: 17014720].
98 Douglas SM, Montelione GT, Gerstein M. PubNet: a flexible system for visualizing literature derived networks. Genome Biol. 2005;6(9):R80. [pmid: 16168087].
99 Zhang Y, Sarkar IN, Chen ES. PubMedMiner: mining and visualizing MeSH-based associations in PubMed. AMIA Annu Symp Proc. 2014;2014:1990-9. [pmid: 25954472].
100 Cohen WW, Singer Y. A simple, fast, and effective rule learner. Proceedings of the Annual Conference of the American Association for Artificial Intelligence (AAAI). 1999:335-42.
101 Mierswa I, Wurst M, Klinkenberg R, et al. YALE (now RapidMiner): rapid prototyping for complex data mining tasks. Proc ACM SIGKDD Int Conf on Knowl Discov Data Mining. 2006.
102 Pafilis E, O'Donoghue SI, Jensen LJ, et al. Reflect: augmented browsing for the life scientist. Nat Biotechnol. Jun. 2009;27(6):508-10. [pmid: 19513049].
103 Vazquez M, Carmona-Saez P, Nogales-Cadenas R, et al. SENT: semantic features in text. Nucleic Acids Res. Jul. 2009;37(Web Server issue):W153-9. [pmid: 19458159].
104 Kuhn M, Campillos M, Letunic I, et al. A side effect resource to capture phenotypic effects of drugs. Mol Syst Biol. 2010;6:343. [pmid: 20087340].
105 Marshall C, Brereton P, Kitchenham B. Tools to support systematic reviews in software engineering: a feature analysis. Conference Proceedings. EASE '14: Proceedings of the 18th International Conference on Evaluation and Assessment in Software Engineering. May 13, 2014. London.
106 Hernandes E, Zamboni A, Fabbri S, Di Thommazo A. Using GQM and TAM to evaluate StArt -- a tool that supports systematic review. CLEI Electron J. Apr. 2012;15(1). paper 2.
107 Fabbri S, Hernandes E, di Thommazo A, et al. Managing literature reviews information through visualization. Conference Proceedings. 14th International Conference on Enterprise Information Systems (ICEIS 2012). June 28, 2012. 36-45.
108 Bowes D, Hall T, Beecham S. SLuRp - a tool to help large complex systematic literature reviews deliver candid and rigorous results. Conference Proceedings. 2nd International Workshop on Evidential Assessment of Software Technologies, EAST 2012. September 22, 2012. 33-6.
109 Yang JJ, Cohen AM, Cohen A, et al. SYRIAC: The systematic review information automated collection system a data warehouse for facilitating automated biomedical text classification. AMIA Annu Symp Proc. 2008:825-9. [pmid: 18999194].
110 Feinerer I, Hornik K, Meyer D. Text mining infrastructure in R. J Stat Software. Mar. 2008;25(5):1-54.
111 Eck N, Waltman L. Software survey: VOSviewer, a computer program for bibliometric mapping. Scientometrics. 2010;84(2):523-38. [pmid: 20585380].
112 Sarker A, Molla D, Paris C. Automatic evidence quality prediction to support evidence-based decision making. Artif Intell Med. Jun. 2015;64(2):89-103. [pmid: 25983133].
113 Rebholz-Schuhmann D, Arregui M, Gaudan S, et al. Text processing through Web services: calling Whatizit. Bioinformatics. Jan. 15. 2008;24(2):296-8. [pmid: 18006544].
114 Perez-Iratxeta C, Perez AJ, Bork P, et al. Update on XplorMed: A web server for exploring scientific literature. Nucleic Acids Res. Jul. 1. 2003;31(13):3866-8. [pmid: 12824439].