# Introduction

## Background

Systematic reviews have been defined as “attempts to collate all empirical evidence that fits prespecified eligibility criteria in order to answer a specific research question. It uses explicit, systematic methods that are selected with a view to minimizing bias, thus providing more reliable findings from which conclusions can be drawn.”1 While the production of systematic reviews is a cornerstone of evidence-based practice, the cost and time required to conduct many systematic reviews are concerns.1,2 In recent years, the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program through the Evidence-based Practice Center (EPC) Program has been engaged in methodologic research on how systematic reviews can be conducted more efficiently, including research on rapid review methods, the utilization of text mining/machine learning in the screening process and for updating reviews, and the development of Abstrackr.3-5

For the purposes of this white paper, we adopted Thomas et al.'s broad definition of text mining within the systematic review context as a method “to retrieve information from unstructured text and to present the distilled knowledge to users…. [which] comprises three major activities: information retrieval which retrieves texts relevant to the user's query; information extraction which identifies and extracts snippets of textual fragments related to the query; and data mining, which finds direct and indirect associations among the pieces of information extracted from texts.”6 For readers interested in more specific categories of tools and their functionality, Miner et al. have defined the following seven areas of practice within the text-mining field:7

- Document classification – grouping and categorizing snippets, paragraphs, or documents, using data mining classification methods, based on models trained on labeled examples
- Document clustering – grouping and categorizing terms, snippets, paragraphs, or documents, using data mining clustering methods
- Information retrieval – storage and retrieval of text documents, including search engines and keyword search
- Concept extraction – grouping of words and phrases into semantically similar groups
- Information extraction – identification and extraction of relevant facts and relationships from unstructured text; the process of making structured data from unstructured and semistructured data
- Natural language processing – low-level language processing and understanding tasks (e.g., tagging part of speech); often used synonymously with computational linguistics
- Web mining – data and text mining on the Internet, with a specific focus on the scale and interconnectedness of the web

Table 1 offers a brief overview of how text-mining tools have been used in various systematic review processes, followed by their relative advantages and disadvantages compared to traditional methods.

Table 1 Text-mining tool use(s) and advantages/disadvantages by SR process step

SR Process Step | How TM Used | Advantages / Disadvantages
Literature Search | Identification of:; - keywords; - synonyms; - subject terms; Filter creation | Identification of keywords, etc.: Advantage: Supports easy review of a far larger corpus of preliminary results for identification of keyword/subject search terms than would be feasible otherwise (potential to improve time efficiency, use of reproducible/objective method, and improved search strategies) Disadvantage: Most TM tools geared to search Medline/PubMed so will likely not be useful for topics in other disciplines Filter creation: Advantage: Creation of reusable tool to identify citations in a database (use of reproducible/objective method and improved search strategies) Disadvantage:; 1. Filter development takes time that may/may not be warranted given search topic; 2. Filters tend to be very sensitive and may return too many results to be useful to review team
Screening Citations | Prioritization of most relevant citations first Fulfilling second screener role | Prioritization: Advantage: Relevant citations are displayed first for screening review, so review team can begin work on these while completing review of all citations (potential to improve process) Second Screener: Advantage: TM tool determines relevant citations and compares against human screener's selections (potential for time efficiency) Disadvantage: Potential for missing relevant citations
Abstracting Data | Information extraction:; - Population; - Intervention; - Condition; - Outcome | Advantage: Validation of human extracted data (potential for time efficiency and increased accuracy) Disadvantage: Not currently ready to be used without human oversight; additional TM tool development and evaluation required
Quality Appraisal | Risk of bias | Advantage: Validation of human appraisal (potential for time efficiency and increased accuracy) Disadvantage: Not currently ready to be used without human oversight; additional TM tool development and evaluation required
Review Updating | Identification of new studies | Advantage: Potential for time efficiency Disadvantage: Not currently ready to be used without human oversight; additional TM tool development and evaluation required

TM = text mining; SR = systematic review

As of this writing, official methods guidance on the use of text-mining tools in systematic reviews has yet to be issued by any of the following prominent organizations in their methods publications: AHRQ Effective Health Care Program (Methods Guide for Effectiveness and Comparative Effectiveness Reviews), Campbell Collaboration (Campbell Collaboration Systematic Reviews: Policies and Guidelines), Cochrane Collaboration (Cochrane Handbook for Systematic Reviews of Interventions), Evidence for Policy and Practice Information and Coordinating Centre (Methods for Conducting Systematic Reviews), Institute of Medicine (Finding What Works in Health Care: Standards for Systematic Reviews), or the Joanna Briggs Institute (Joanna Briggs Institute Reviewers' Manual).1,2,8-11 While the European Network for Health Technology Assessment's HTA Core Model® version 2.1; 2015 does not contain guidance on text-mining, it recently published another guideline titled, Process of Information Retrieval for Systematic Reviews and Health Technology Assessments on Clinical Effectiveness, that advises using word frequency analysis to develop search strategies.12,13 In the future, such guidance will hopefully be published to give greater clarity to when its use is advisable and standards for reporting its use in systematic reviews.

## Purpose of This Report

This project's overall aim was to investigate the use of text-mining tools as an emerging methodology within the context of systematic reviews. This preliminary sketch covers three core areas:

1. To describe the state of published evidence on the use of text mining within systematic review processes (i.e., searching, abstract screening);
2. To better understand issues arising from the use of text-mining technologies from an organizational perspective (i.e., senior investigators) and from a systematic review team member (i.e., information specialists) perspective;
3. To identify and create a core list of text-mining tools that have been used within a systematic review, develop a descriptive tool to broadly characterize them (e.g., “trialability,” free vs. fee, algorithm type), and apply that to the list of tools.