# Peer Reviewers

Prior to publication of the white paper, we sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified

The list of Peer Reviewers follows:

- Karen A. Robinson, Ph.D., M.Sc.
  Director
  Johns Hopkins University Evidence-based Practice Center
  Baltimore, MD
- Nila Sathe, M.A., M.L.I.S.
  Assistant Director
  Vanderbilt University Evidence-based Practice Center
  Nashvillle, TN