# Key Informants

In designing the study questions, the EPC consulted eight Key Informants (KIs), who were chosen to represent different perspectives on the use of text-mining tools within the systematic review process (i.e., from an organizational/programmatic perspective and from an end-user information specialist/research team member perspective). Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual KIs.

KIs must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as text-mining software users, individuals with potential conflicts may be retained. The Task Order Officer and the workgroup endeavored to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Ahmed Abou-Setta, M.D., Ph.D.
  Assistant Professor
  University of Manitoba
  Winnipeg, Manitoba, Canada
- Wichor M. Bramer, M.Sc.
  Biomedical Information Specialist
  Medical Library
  Erasmus Universiteit
  Rotterdam, the Netherlands
- Julie Glanville, M.Sc.
  Associate Director
  York Health Economics Consortium Ltd.
  University of York
  York, United Kingdom
- Elke Hausner, M.Sc.
  Research Associate
  Information Management
  Institut für Qualität und Wirtschaftlichkeit im Gesundheitswesen
  Cologne, Germany
- Mike Kelly, Ph.D., Hon. FRCP, FRCPE, FFPH
  Senior Visiting Fellow
  Department of Public Health and Primary Care
  Institute of Public Health
  University of Cambridge
  Cambridge, United Kingdom
- Claire Stansfield, M.Sc.
  Information Scientist
  Evidence for Policy and Practice Information and Coordinating-Centre
  University College London
  London, United Kingdom
- James Thomas, Ph.D., M.A., M.Mus., GGSM
  Associate Director
  Evidence for Policy and Practice Information and Coordinating-Centre
  University College London
  London, United Kingdom
- Thomas Trikalinos, M.D., Ph.D.
  Associate Professor and Director
  Center for Evidence-based Medicine
  Brown University
  Providence, RI, USA