# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officers, Lionel L. Bañez, M.D., and Elise Berliner, Ph.D. In addition, we thankfully acknowledge Michael Phillips, Kitty Donahue, Helen Dunn, Tracey Monastero-Stem, and Jessica Gontarek for their document preparation support.