# Discussion

## What Was Known and What This Paper Adds

Text-mining techniques have been explored at every phase of the systematic review production process. Screening and data extraction have been studied more extensively than information retrieval and specialized tasks such as quality assessment and updating. Common limitations were a dependence on PubMed/Medline content, nonstandardized tools that require a familiarity with programming, and heterogeneity between studies that precludes analysis. Most authors and KIs considered text mining and machine learning to be very promising to reduce workload for systematic review teams, although they suggest adding these tools as adjuncts rather than as a means of replacing existing tools or displacing team members. The interviews conducted with senior investigators from systematic review organizations and librarians are the first to investigate the experiences and perspectives of these groups with text-mining tools. While the interviews revealed an enthusiasm for the continuing development in the use of these technologies, they also suggest some presumptive benefits have not been adequately studied to date, nor has the scope of their utility been fully described. Our literature review identified no descriptive or performance appraisal instruments of text-mining tools within the context of systematic reviews in medicine and health sciences, indicating a need to develop additional decision support and analysis tools.

Based on this preliminary exploration, we believe that text-mining tools will be increasingly featured within the repository of resources to support the conduct of systematic reviews. Text mining and its related forms of automated knowledge discovery tasks are unlikely to displace current literature retrieval and management tools. Rather, we expect that text mining will augment existing literature-retrieval techniques and information extraction tools. Text mining may be a promising resource to detect unknown relationships and patterns from an expansive archive on unstructured data, but it offers a limited “return on investment” for well-developed processes such as systematic literature searching using controlled vocabulary. Furthermore, the benefits of using a text-mining tool may be limited, in part, by the complexity and size of the relevant literature for a given topic.

## Challenges and Barriers

One key barrier to consider when investigating text-mining tools to support the systematic review methods is lack of information about underlying rules, ontologies, and algorithms. Individuals without experience or training are unlikely to understand how the system or tool works and may be deterred from adopting a tool that does not provide installation instructions or a user guide. Therefore, in our assessment, we included a category for “help” to distinguish the sources that may be a better starting place for a potential user with limited knowledge of text-mining technology. For the tools that provided documentation, the usefulness varied; however, those tools with documentation appeared more accessible among the expansive and diverse set of options. The GATE open-source software is one project that explicitly addresses this challenge, noting that, over 20 years, developers have “spent a great deal of effort deconstructing the black box semantic platform” and, that in addition to being open source, GATE-based solutions include “numerous plug and play components and users can see where the rule sets or the ontology or the algorithms fit” to offer users greater insight into how their systems work.60

## Pragmatic Considerations

Based on our literature review, interviews with KIs, and descriptive assessment of text-mining tools, we offer the following pragmatic considerations:

- Socio-technological barriers to adoption (e.g., staff integration issues, methodologic criticism by others in the systematic review community.
- Organizational IT security systems may forestall or hamper the functionality of some text-mining tools.
- “Integratability” of text-mining tools into existing workflows and with other organizational IT systems.
- Reporting use of text-mining tools is undeveloped by well-known systematic review methodology organizations, resulting in their use often going unreported or heterogeneously reported.

For current non-users, the decision to adopt text-mining into the systematic review process will likely be influenced by the first three considerations. With regard to the fourth consideration, guidelines for reporting the use of text-mining tools in prospective systematic reviews would be optimal and are likely to aid in assessment of reproducibility and validation as well as comparative evaluation of these tools.

Additionally, it is imperative that one or more of the methodologists on the systematic review team understand the parameters, limitations, and implications of the text-mining features and functions. Many tools rely on algorithms or statistical analyses that may be unfamiliar to the individuals who typically manage literature searching and retrieval, conduct screening, and/or data extractions. Thus, teams should consider consulting with a biostatistician and/or a computer programmer before introducing a text-mining application into the systematic review to ensure that the tool generates meaningful and reliable results that can be replicated.

## Strengths and Limitations

To our knowledge, this is the first narrative review of published research on text-mining tools use across all types of reviews and all steps in the systematic review process from a wide variety of disciplines (e.g., computer science, library and information science, medicine). It should be noted that due to time constraints, this project is not a comprehensive review, so additional unidentified materials of interest may exist. Results were limited to English-language materials published since 2005.

We solicited a range of perspectives by interviewing KIs from two groups of systematic review researchers a novel source of information on this topic; however, our sample size was small so these preliminary findings bear further investigation. Other investigators, librarians, or end-user groups might have different perspectives than those we interviewed for this project. Due to unsuccessful recruitment attempts, the workgroup did not include a computer scientist, which may have influenced this report's conduct or conclusions.

Lastly, this study includes the first compilation of text-mining tools used in published systematic reviews, described in the research literature, or mentioned by one of the KIs. We created a descriptive tool to characterize and compare broad attributes (e.g., cost, desktop- or server-based) of available tools. Creating a comparative performance evaluation test and conducting the requisite evaluation of the tools was out of the scope of this project.

This is not necessarily an exhaustive index or a validated method of feature analysis or tool evaluation. Several assessments (e.g., whether a tool is applicable or could be used to support a systematic review) were based on the subjective judgment of team members. However, we relied on informal thresholds to apply consistent judgments. The term “text mining” frequently captures tools designed to extract and classify granular information from the molecular biology literature. Although similar in concept and underlying mechanism, we did not include those in our catalog. Assessments were conducted by information specialists who primarily conduct literature searches for systematic reviews of health care interventions and is therefore biased to reflect the experience, skills, and vocabulary reflective of this discipline. An evaluation of the same tools by experts from other domains (e.g., computer science, genetics, engineering, bioinformatics) is likely to generate different conclusions about the features and usefulness.

## Future Directions

### Tools

Next steps for examining the features and usefulness of text-mining tools to support systematic reviews should include simulation and replication studies using actual systematic reviews and/or case studies to assess performance.34 Our assessment was preliminary and limited to mapping characteristics and judging usability among a subset of text-mining tools most likely to support systematic review methods. With numerous sources of tools and a variety of ways to leverage text-mining technology, it is critical to consider how to cull a subset of those most likely to improve quality or boost efficiency of existing processes.

Before designing an evaluation or validation study, it is essential to consider the specific needs and define the expected value of a text-mining tool or technology within the systematic review process. The approach to selecting and benchmarking a tool varies by the intended application within the systematic literature review process. Automated text and document categorization, retrieval, and classification features may help reduce or redistribute workload, improve search sensitivity, prioritize a set of interventions or outcomes of interest, or refine the scope for a topic with a large literature base. Selection and analysis of features will differ based on the context and purpose. Existing case studies using text-mining tools or technologies described in the literature may be helpful in planning a detailed evaluation or performance assessment. Examples span disciplines and investigate various applications, including automated annotation of functional imaging experiments,61 text mining to detect drug discontinuation rates,62 word frequency analysis to validate a patient safety search strategy,33 narrative text interrogation of administrative health data for injury surveillance,63 and automated document classification to prioritize workload for systematic reviews.58

The underlying computational methods that power a tool are not always described for or apparent to the user. Thus, a robust evaluation requires either knowledge of the underlying technologies or access to descriptions of the tool features and development and technical resources for installation and application support. Key characteristics of text-mining tools selected for systematic review support should include reliability and transparency of the computational methods; ease of use, including support for different formats of text and data; and results that are replicable and compatible with the tools and workflow currently in use.