# Tools Catalog

Table E-1 Tools evaluation table

Name Acronym URL | Availability^a^ Cost | Web Based^b^ | Platform | Developer | Multiuser^b^ | KI^b^ | Lit Review a Citation(s) | Publication(s)^a^ | SR Support^a^ | Deploy Status^a,b^ | Tech Level^a^ | Features^a^ | Help^b^ | Registration^a,b^ | Comments
Abstrackr http://abstrackr.cebm.brown.edu/account/login | FR 0 | 1 | NA | Brown University | 1 | 1 | 14 | 52 | IE | 1 | 0 | ND | ND | 1 | ND
Anne O'tate http://arrowsmith.psych.uic.edu/cgi-bin/arrowsmith_uic/AnneOTate.cgi | FR 0 | 1 | NA | Department of Psychiatry and Psychiatric Institute, University of Illinois at Chicago | 0 | 0 | 16 34 64 | 64 | TR FI | 1 | 0 | IR DCL ATM TSM | ND | 0 | ND
AntCont http://www.laurenceanthony.net/software/antconc/ | FR 0 | 0 | MULTI | Laurence Anthony | UC | 1 | ND | ND | TR FI | 1 | 1 | ATM DCL | 1 | ND | Requires installation
AQ21 machine learning software http://www.mli.gmu.edu/software | FR 0 | 0 | MULTI | Janusz Wojtusiak | UC | 0 | 65 | ND | ND | 1 | ND | ND | 1 | 0 | Requires installation
Aquad http://www.aquad.de/en/ | FR 0 | 0 | MULTI | Gunter L. Huber | UC | 0 | ND | ND | ND | 1 | ND | ND | ND | ND | Requires installation
askMEDLINE http://askmedline.nlm.nih.gov/ask/ask.php | FR 0 | 1 | NA | National Library of Medicine | 0 | 0 | 16 | 66 | TR FI | 1 | 0 | NLP IR | ND | ND | ND
Automated Sequence Annotation Pipeline (ASAP) http://bioinformatics.fccc.edu/software/OpenSource/ASAP/ASAP.shtml | FR 0 | 0 | MULTI | Fox Chase Cancer Center | UC | 0 | 54 | 67 | IE | 1 | 2 | DCL NLP | 1 | 0 | ND
BioIE http://www.bioinf.manchester.ac.uk/dbbrowser/bioie/ | FR 0 | 1 | NA | The University of Manchester, Bioinformatics | 0 | 0 | ND | 68 | TR FI | 1 | 0 | ND | ND | 0 | ND
BioTextQuest | FR 0 | 1 | NA | University of Crete | 0 | 0 | 34 | 69 | TR FI | 1 | 0 | DCL NLP VIZ | ND | 0 | Web site cannot be displayed
carrott2 http://project.carrot2.org/download-workbench-win32-64bit.html | FR 0 | 0 | MULTI | David Weiss and Stanislaw Osinksi | 0 | 1 | 70 34 | ND | DCT | 1 | ND | ND | 1 | ND | Requires installation
Cassandre http://cassandra.apache.org/ | FR 0 | 0 | MULTI | Apache Software Foundation | ND | 0 | ND | ND | ND | ND | 2 | ND | ND | ND | Probably out of scope
Chilibot http://www.chilibot.net/ | FR 0 | 1 | NA | University of Tennessee Health Science Center | 0 | 0 | 16 | 71 | TR FI | 1 | 0 | NLP IR VIZ ATM | 1 | 0 | ND
Coding Analysis Toolkit (CAT) http://cat.ucsur.pitt.edu/ | FR 0 | 0 | MULTI | Qualitative Data Analysis Program, University of Pittsburgh | 0 | 0 | ND | ND | IE EX | 1 | 2 | DCL IEX | 1 | ND | Requires installation
Computer Aided Textual Markup & Analysis (CATMA) http://www.catma.de/ | FR 0 | 1 | NA | University of Hamburg | ND | 0 | ND | ND | ND | ND | ND | ND | 1 | 1 | Literary analysis
Concordance http://www.concordancesoftware.co.uk/ | FRT 0 | 0 | MULTI | R. J. C. Watt | 0 | 0 | 37 36 | ND | ND | ND | ND | ND | ND | ND | Requires installation
CoPub http://services.nbic.nl/copub/portal/ | FR 0 | 1 | NA | Computational Drug Discovery Group of Radboud University Nijmegen Medical Centre | 0 | 0 | 16 | 72 | TR FI | 1 | 0 | NLP | ND | 0 | ND
COREMINE medical http://www.coremine.com/medical/#search | FR 0 | 1 | NA | PubGene AS | 0 | 0 | 16 | ND | TR FI | 1 | 0 | NLP ATM IR VIZ | 1 | 0 | ND
Dbpedia http://wiki.dbpedia.org/ | FR 0 | 0 | MULTI | Dbpedia | 0 | 0 | ND | 73 | ND | ND | ND | ND | ND | ND | Requires installation
EndNote http://endnote.com/ | CP varies | 1 | MULTI | Thomas-Reuters | 1 | 1 | 46 | 46 | ND | 1 | ND | ND | ND | ND | ND
EPPI-Reviewer 4 (EPPI) http://eppi.ioe.ac.uk/cms/Default.aspx?tabid=1913 | FRT UC | 1 | NA | Evidence for Policy and Practice Information and Coordinating Centre, UCL Institute of Education, University of London | 1 | 1 | 14 | ND | IE EX | 1 | 1 | ATM DCT DCL | 1 | 1 | ND
ETBLAST http://etest.vbi.vt.edu/etblast3/ | FR 0 | 1 | NA | Virginia Bioinformatics Institute | 0 | 0 | 16 | 74 | TR FI | 1 | 0 | NLP | 1l | 0 | ND
ExaCT Not found | ND ND | ND | ND | ND | ND | 0 | ND | 75 | EX | ND | ND | ND | ND | ND | ND
FACTA+ http://www.nactem.ac.uk/facta/ | FR 0 | 1 | NA | National Centre for Text Mining, School of Computer Science, The University of Manchester | 0 | 0 | 16 | 76 | TR FI EX | 1 | 0 | NLP IR IEX | 1 | 0 | ND
FreeQDA https://github.com/produnis/FreeQDA/downloads | FR 0 | 0 | ND | ND | 0 | 0 | ND | ND | ND | ND | ND | ND | ND | ND | Requires installation
GAPScreener http://www.hugenavigator.net/HuGENavigator/HNDescription/opensource_GAP.htm | FR 0 | 0 | MULTI | Wei Yu, National Office of Public Health Genomics, Centers for Disease Control and Prevention | UC | 1 | ND | 77 | TR FI IE | 1 | 2 | IEX | ND | ND | Requires installation; human genome epidemiology network
GATE https://gate.ac.uk/ | FR 0 | 0 | MULTI | University of Sheffield | UC | 1 | 78 | 60 | TR FI IE | 1 | 2 | TCL | 1 | ND | Requires installation
Gopubmed http://www.gopubmed.org/web/gopubmed/ | FR 0 | 1 | NA | Transinsight GmbH | 0 | 1 | 16 34 35 | 79 | TR FI | 1 | 0 | NLP | 1 | 1 | ND
Hierarchical Cluster Explorer (HCE) http://www.cs.umd.edu/hcil/hce/ | FR 0 | 0 | WIN | Human-Computer Interaction Lab, University of Maryland | UC | 0 | 78 | 80 | ND | ND | ND | ND | ND | ND | Requires installation
HubMed http://git.macropus.org/hubmed/ | FR 0 | 1 | NA | ND | 0 | 0 | ND | 81 | TR FI | 1 | 0 | NLP | 1 | 0
HuGENet http://www.hugenavigator.net/HuGENavigator/HNDescription/opensource_GAP.htm | FR 0 | 1 | NA | ND | ND | 1 | ND | ND | ND | ND | ND | ND | ND | ND | ND
Idealist Unavailable | ND ND | ND | ND | ND | ND | 0 | 36 | ND | ND | ND | ND | ND | ND | ND | Blackwell bibliographic software
KH Coder http://khc.sourceforge.net/en/ | FR 0 | 0 | MULTI | Koichi Higuchi | UC | 0 | ND | 82 | ND | ND | ND | ND | ND | ND | Requires installation
Konstanz Information Miner (KNIME) https://www.knime.org/ | FR 0 | 0 | NA | KNIME | UC | 0 | ND | ND | ND | ND | ND | ND | ND | 1 | Requires installation
LEXIMANCER http://info.leximancer.com/ | FRT varies | 1 | NA | Leximancer | 1 | 0 | 41 | ND | ND | ND | ND | ND | ND | ND | Requires installation
libSVM http://ntucsu.csie.ntu.edu.tw/∼cjlin/libsvm/ | FR 0 | 0 | MULTI | Chih-Chung Chang and Chih-Jen Lin | UC | 0 | 40 | ND | IE | 1 | 2 | DCL | ND | ND | Requires installation
Lingo3G http://carrotsearch.com/lingo3g-overview | FRT varies | 0 | MULTI | Carrot | UC | 1 | 83 | ND | ND | ND | ND | TCL VIZ | ND | ND | Requires installation
LingPipe http://alias-i.com/lingpipe/ | FR 0 | 0 | WIN | Alias-i | UC | 0 | 84 | ND | EX | 1 | 2 | IEX | 1 | ND | Requires installation
linguamatics (I2E) http://www.linguamatics.com/welcome/software/I2E.html | CP varies | 1 | NA | Linguamatics | UC | 0 | ND | 85 | ND | ND | ND | NLP | ND | ND | Trial includes subset of data
Machine Learning for Language Toolkit (MALLET) http://mallet.cs.umass.edu/ | FR 0 | 0 | MULTI | Andrew McCallum, University of Massachusetts | UC | 0 | ND | ND | ND | 1 | 2 | NLP DCL IEX | 1 | ND | Requires installation
MEDIE http://www.nactem.ac.uk/medie/ | FR 0 | 1 | NA | Tsujii Laboratory | 0 | 0 | 16 | 86 | TR FI | 1 | 0 | NLP IR ATM | 0 | ND | ND
Medline Ranker http://cbdm-01.zdv.uni-mainz.de/∼jfontain/cms/?page_id=4 | FR 0 | 1 | NA | Computational Biology and Data Mining group, Miguel Andrade-Navarro, Johannes Gutenberg University Mainz | 0 | 0 | 16 34 | ND | TR FI | 1 | 0 | ATM TCL | 1 | ND | ND
medsum http://webtools.mf.uni-lj.si/public/medsum.html | FR 0 | ND | ND | ND | ND | 0 | 34 | 87 | ND | ND | ND | ND | ND | ND | ND
MeSHY http://tools.bat.infspire.org/meshy/ | FR 0 | 1 | NA | Bioinformatics Analysis Team | 0 | 0 | 87 | 88 | TR FI | 1 | 1 | IR TCL | ND | ND | ND
MetaMap http://metamap.nlm.nih.gov/ | FR 0 | 0 | ND | Alan Aronson, National Library of Medicine | ND | 0 | 38 64 | 89 | ND | ND | ND | ND | 1 | ND | Out of scope
Meva http://www.med-ai.com/meva/ | FR 0 | 1 | ND | Institute for Medical Statistics and Epidemiology, Technical University of Munich | 0 | 0 | ND | 90 | TR FI | 1 | 1 | ATM TCL | 1 | ND | ND
Mscanner http://mscanner.stanford.edu/ | FR 0 | 1 | NA | Graham Poulter | 0 | 0 | 43 | 91 | TR FI | 1 | 0 | DCL IR | 1 | ND | ND
MyMiner http://myminer.armi.monash.edu.au/ | FR 0 | 1 | NA | Australian Regenerative Medicine Institute, Monash University | 0 | 0 | NA | 92 | TR FI | 1 | 1 | TCA | 1 | ND | ND
NLM Medical Text Indexer (MTI) http://ii.nlm.nih.gov/MTI/ | FR 0 | ND | ND | ND | ND | 0 | ND | 93 | TR FI | ND | ND | NLP | ND | ND | ND
Nvivo http://www.nvivo10.com/en/whats-new.html | CP varies | 0 | MULTI | QSR | UC | 0 | 15 | ND | ND | 1 | 1 | TCA | 1 | ND | Requires installation
OpenNLP https://opennlp.apache.org/ | FR 0 | 0 | MULTI | Apache Software Foundation | UC | 0 | 54 | ND | IE | 1 | 1 | TCA | ND | ND | ND
Perceptron classifier http://reference.wolfram.com/applications/neuralnetworks/NeuralNetworkTheory/2.4.0.html | NA NA | NA | NA | NA | NA | 1 | 94 | ND | ND | NA | 2 | ND | NA | ND | Classifier algorithm
PICO http://pubmedhh.nlm.nih.gov/nlmd/pico/piconew.php | FR 0 | 1 | NA | National Library of Medicine | 0 | 0 | 16 | ND | TR FI | 1 | 0 | IR | ND | ND | ND
Pimiento http://erabaki.ehu.es/jjga/pimiento/ | FR 0 | 0 | MULTI | Juan Jose Garcia Adeva | UC | 0 | 14 | 95 | ND | 1 | 2 | DCT TSM | ND | ND | Requires installation
PPIinterFinder http://www.biominingbu.org/ppinterfinder/about.html | FR 0 | 1 | NA | Data Mining and Text Mining Laboratory, Department of Bioinformatics, Bharathiar University | 0 | 0 | ND | ND | ND | ND | ND | ND | ND | ND | Protein-protein interactions
Projection Explorer (PEx) http://infoserver.lcad.icmc.usp.br/infovis2/PEx | FR 0 | 0 | MULTI | Fernando Vieira Paulovich, University of Sao Paulo | UC | 0 | 96 | ND | TR | UC | 2 | VIZ | ND | ND | ND
PubCrawler http://pubcrawler.gen.tcd.ie/ | FR 0 | 1 | NA | Ken Wolfe Lab, Genetics Department Trinity College | 0 | 0 | 16 | 97 | TR FI | 1 | 0 | IR | 1 | 1 | ND
PubGet http://pubget.com/ | FR 0 | 1 | NA | ND | ND | 0 | 16 | ND | ND | ND | ND | ND | ND | ND | ND
PubMatrix http://pubmatrix.grc.nia.nih.gov/ | FR 0 | 1 | NA | National Institute of Health | 0 | 0 | 16 34 | 98 | TR FI | 1 | 1 | IR | ND | 1 | Registered but unable to login
PubNet http://pubnet.gersteinlab.org/ | FR 0 | 1 | NA | Gerstein Lab, Department of Molecular Biophysics and Biochemistry, Yale University | 0 | 0 | 16 | 99 | TR FI | 1 | 1 | IR VIZ | 1 | ND | ND
PubReMiner http://hgserver2.amc.nl/cgi-bin/miner/miner2.cgi | FR 0 | 1 | NA | Jan Koster, Academic Medical Center | 0 | 1 | 42 | ND | TR FI | 1 | 0 | TCL IR | 1 | ND | Standalone for searching
PubViz https://github.com/aha01/PubViz/ | FR 0 | 0 | MULTI | Matthias Fabi, Andrea Haberson, San Rasul, Elisabeth Schnaitt, Paul Theisen | 0 | 0 | 16 | ND | TR FI | 1 | 1 | VIZ | 1 | ND | Requires installation
QCAmap http://www.qualitative-content-analysis.aau.at/software/ | FR 0 | 1 | NA | Philipp Mayring, Thomas Fenzl | 0 | 0 | ND | ND | ND | ND | ND | ND | 1 | yes | Qualitative content analysis
QDA Miner http://provalisresearch.com/products/qualitative-data-analysis-software/ | FR 0 | 0 | WIN | Provalis Research | 1 | 0 | ND | ND | ND | 1 | 1 | ND | ND | ND | Qualitative content analysis
Qiqqa http://www.qiqqa.com/Download | FR 0 | 1 | WIN ADR | ND | 0 | 0 | ND | 82 | TR FI EX | 1 | 1 | DCL CLA | 1 | ND | Premium features with paid subscription
Quetzal https://www.quetzal-search.info/loginpage | FRT varies | 1 | NA | Quertle LLC | UC | 0 | 16 | 100 | TR FI EX | 1 | 1 | IR DCL | ND | 1 | Key concepts available with paid subscription; previously Quertle
r Simple Learner with Iterative Pruning to Produce Error Reduction (SLIPPER) | ND ND | ND | ND | ND | ND | 0 | 94 | 101 | ND | ND | ND | ND | ND | ND | Rule learning algorithm
RapidMiner https://rapidminer.com/ | CP varies | 1 | NA | RapidMiner | UC | 0 | 14 | ND | ND | 1 | 1 | ND | ND | ND | Requires installation
Rayyan http://rayyan.qcri.org/ | FR 0 | 1 | NA | QCRI | 1 | 0 | ND | ND | IE | 1 | 0 | ND | ND | 1 | ND
RCT Tagger http://arrowsmith.psych.uic.edu/cgi-bin/arrowsmith_uic/RCT_Tagger.cgi | FR 0 | 1 | NA | Cohen et al. | 0 | 0 | 56 | 102 | FI IE | 1 | 0 | DCL | ND | 0 | ND
Reflect http://reflect.embl.de/ | FR 0 | 1 | NA | European Molecular Biology Laboratory | 0 | 0 | 16 | 53 | ND | 1 | 0 | ND | ND | ND | Gene and protein tagging tool
RobotReviewer http://vortext.systems/robotreviewer | FR 0 | 1 | MULTI | ND | UC | 0 | 53 | ND | EX | 1 | 1 | IEX | ND | ND | Web version for testing; requires installation
RQDA http://rqda.r-forge.r-project.org/ | FR 0 | 0 | MULTI | ND | UC | 0 | ND | 103 | ND | ND | ND | ND | ND | ND | Requires installation; qualitative content analysis
Semantic Medline http://skr3.nlm.nih.gov/SemMed/index.html | FR 0 | 1 | MULTI | Fiszman, Marcelo | 0 | 0 | ND | 104 | ND | 1 | 0 | NLP | 1 | 1 | Requires registration; extract semantic predication
SIDER 2 http://sideeffects.embl.de/drugs/4158/ | FR 0 | 1 | NA | Michael Kuhn, Structural and Computational Biology Unit, European Molecular Biology Laboratory | ND | 0 | ND | ND | ND | 1 | 0 | IEX | ND | 1 | ND
SimStat http://provalisresearch.com/products/simstat/ | CP varies | 0 | MULTI | Provalis Research | UC | 1 | ND | ND | ND | 1 | 2 | ND | ND | ND | Requires installation; qualitative and quantitative statistical package
Site Content Analyzer http://www.cleverstat.com/en/sca-website-analysis-software-index.htm | OTH 79 | 0 | WIN | CleverStat | UC | 0 | 78 | ND | ND | UC | UC | UC | 1 | ND | Requires installation; website content parser
SLRTOOL http://slrtool.org/v0 | FR 0 | 1 | NA | ND | 1 | 0 | 105 | ND | ND | 0 | 1 | UC | 0 | 1 | ND
SPSS http://www-01.ibm.com/software/analytics/spss/ | CP varies | 0 | MULTI | IBM | UC | 0 | 36 | 106 | ND | 1 | 1 | ND | 1 | ND | Requires installation
State of the Art through systematic review (StArt) http://lapes.dc.ufscar.br/tools/start_tool | FR 0 | 0 | MULTI | Laboratory of Research on Software Engineering, Computing Department of the Federal University of São Carlos | UC | 0 | 107 78 105 | ND | FI EX | 1 | 2 | IEX TCL | 1 | ND | Requires installation
STRING http://string-db.org/ | FR 0 | 1 | NA | Swiss Institute of Bioinformatics | 0 | 0 | 16 | 108 | ND | ND | ND | ND | 1 | ND | Protein-protein interactions
Systematic Literature unified Review Program (SLuRp) https://codefeedback.cs.herts.ac.uk/SLuRp/ | FR 0 | 0 | MULTI | David Bowes, Science and Technology Research Institute University of Hertfordshire | 1 | 0 | 78 105 | 109 | FI IE EX | 1 | 2 | IEX | ND | ND | ND
Systematic review supported by visual analytics (REVIS) http://ccsl.icmc.usp.br/pt-br/projects/revis | FR 0 | 0 | UC | University of Sao Paulo | UC | 0 | 14 | 47 | ND | 1 | ND | VIZ | ND | ND | Requires installation
TerMine http://www.nactem.ac.uk/software/termine/ | FR 0 | 1 | NA | Sophia Ananiadou, National Centre for Text Mining | UC | 1 | 40 | ND | IE | 1 | 1 | ATM | 1 | ND | Web version for demonstration; register for batch service
Text Analysis Markup System (TAMS) http://tamsys.sourceforge.net/ | FR 0 | 0 | MAC | Matthew Weinstein | UC | 0 | ND | 110 | ND | 1 | 2 | TCL | 1 | ND | Requires installation; qualitative content analysis
Text Mining Infrastructure in R (tm in R) http://tm.r-forge.r-project.org/ | FR 0 | 0 | MULTI | ND | ND | 1 | 32 | ND | ND | 1 | 2 | DTM | ND | ND | ND
Textpresso http://www.textpresso.org/about.html | FR 0 | ND | ND | ND | ND | 0 | 34 | ND | ND | ND | ND | TCA | ND | ND | Biological literature; entity recognition
TinySVM http://chasen.org/∼taku/software/TinySVM/ | FR 0 | 0 | MULTI | ND | UC | 0 | 70 | ND | FI IE EX | 1 | 2 | ND | ND | ND | Learning algorithms
Ultimate Research Assistant http://www.ultimate-research-assistant.com/GenerateResearchReport.asp | ND ND | ND | ND | ND | ND | 0 | 34 | 54 | ND | ND | ND | ND | ND | ND | ND
Unstructured Information Management Application Framework (UIMA) http://uima.apache.org/ | FR 0 | 0 | WIN | IBM; currently at Apache Software Foundation | UC | 0 | 54 | ND | ND | 1 | 2 | DCL NLP | 0 | ND | Requires validation workstation; out of scope
VOSviewer http://www.vosviewer.com/Home | FR 0 | 0 | MULTI | Centre for Science and Technology Studies, Leiden University | ND | 1 | 111 | ND | ND | ND | 1 | VIZ TCL | ND | ND | ND
Voyant Tools http://voyant-tools.org/ | FR 0 | 1 | NA | Stefan Sinclair and Geoffrey Rockwell | 0 | 1 | ND | ND | ND | 1 | ND | VIZ TCL | 0 | ND | ND
Weka http://www.cs.waikato.ac.nz/ml/weka/ | FR 0 | 0 | MULTI | University of Waikato | ND | 0 | 112 | 113 | ND | ND | ND | ND | ND | ND | Machine learning
Whatizit https://www.ebi.ac.uk/webservices/whatizit/info.jsf | FR 0 | 1 | NA | European Bioinformatics Institute | 0 | 0 | 16 | 46 | TR FI | 1 | 0 | TCL | ND | ND | ND
WordStat http://www.stata.com/news/wordstat-for-stata/ | CP varies | 0 | MULTI | Provalis Research | ND | 1 | 46 | ND | ND | ND | ND | ND | ND | ND | ND
xPDF http://www.foolabs.com/xpdf/home.html | FR 0 | 0 | MULTI | Foolabs | 0 | 0 | 53 | 114 | ND | ND | 0 | TRV | ND | ND | PDF to text utility; not relevant
XplorMed http://xplormed.ogic.ca/ | FR 0 | 1 | NA | Carolina Perez-Iratxeta, Peer Bork, and Miguel A. Andrade | 0 | 0 | 16 | ND | TR FI | 1 | 0 | TCL IR | 1 | ND | ND

Notes:

a See Table E-2 for explanation of fields and answer codes.

b “0”= No; “1”=Yes.

ATM = automatic term recognition; CP = commercial product; DCL = document classification; DCT = document clustering; DTM = document term matrix; EX = data extraction or synthesis; FI = searching collecting, retrieving literature or data; FR = free; FRT = free trial; IE = screening or eligibility assessment; IEX = information extraction; IR = information retrieval; MULTI = multiple; NA = not applicable; ND = no data; NLP = national language processing; OTH = other; TCA = text categorization; TCL = text cluster; TR = topic refinement; TSM = text summarization; TRV = text retrieval; UC = unclear; VIZ = visualization

Note: Fourteen tools were reviewed but not included in the table of characteristics. The tool name, URL, and reason for exclusion:

Aggregator | Not found | Cannot locate; possibly forthcoming; not publicly available
Ali Baba | http://alibaba.informatik.hu-berlin.de/ | Retired
ClusterMed | http://compbio.dfci.harvard.edu/compbio/tools/clustermed | Retired; appears that it is no longer supported or functional
ConceptLink | http://project.cis.drexel.edu/conceptlink | Unavailable; cannot access URL
KNALIJ | http://knalij.com | Unavailable; cannot access URL
LibreQDA | Not found | Cannot locate
Literature and Genetic Electronic Resource and Catalogue | http://ligercat.ubio.org/ | Unavailable; cannot access URL
MiSearch | http://misearch.ncibi.org/ | Not working; site indicates “down for maintenance”
PubFocus | http://www.pubfocus.com/ | Not working; site available but not functional
Pubhub | Not found | Cannot locate
Semantic Features In Text | http://sent.dacya.ucm.es./ | Unavailable; cannot access URL
Spa | Not found | Cannot locate
SYstematic Review Information Automated Collection | Not found | Cannot locate; possibly not publicly available
Weft QDA | http://www.pressure.to/qda/ | Retired; site indicates “(Jun 2014) Since Weft QDA was developed, free (but not open source) versions of some commercial software have emerged (e.g., QDA Miner Lite).”

Table E-2 Evaluation components and choices

Item | Description | Choices
Name | The full name of the tool or resource | Any
Acronym | Acronym or alternate name of the tool or resource | Any
URL | The URL to the web-based tool or resource or to the file download | Any
Availability | Availability, either freely available to all users or proprietary or commercial product | FR, Free\| FRT, Free limited time trial\| CP, Commercial Product\| UC, Unclear\| OTH, Other\| NA, Not Applicable
Cost | Cost of the tool or resource or subscription to services in U.S. dollars | Any
Web-Based | Is the tool accessible for use via the internet using a URL? | 0, No\| 1, Yes\| UC, Unclear
Platform | Supported operating system for tools or resources that require download or installation | WIN, Windows\| MAC, Macintosh \|LIN, Linux\| MULTI, Multiple\| OTH, Other\| UC, Unclear\| NA, Not Applicable
Developer | Company, institution, or individual credited as the developer of the tool or resource | Any
Multiuser | Does the tool or resource support multiple concurrent users for collaboration on an individual project | 0, No\| 1, Yes\| UC, Unclear
Literature | Has literature been identified that describes the development, validation, or evaluation of the tool or resource? | 0, No\| 1, Yes\| UC, Unclear
Citation(s) | List the publication(s) that describe development, validation, or evaluation of the tool or resource. | Any/ link to PubMed UI
Applicability | Is the tool or resource designed to support, or could it be easily modified to support, the conduct of a systematic reviews? | 0, No\| 1, Yes\| UC, Unclear
Prior Use in a Systematic Review | Has the tool or resource previously been used to support a systematic reviews? | 0, No\| 1, Yes\| UC, Unclear
Systematic Review Support | How the tool has been or could be used to support conduct of the systematic review. | TR, topic refinement, scope, or question development\| FI, searching, collecting, retrieving literature or data\| IE, screening or eligibility assessment\| EX, data extraction or synthesis\| OTH, other\| UC, unclear
Deploy Status | Is the tool or resource fully functional and available for use (i.e., not in development or pilot status)? | 0, No\| 1, Yes\| UC, Unclear
Tech Level | Degree of technical expertise or support expected for an average user to install, customize and/or run the tool or resource. | 0, Low\| 1, Medium\| 2, High\| UC, Unclear
Features | Broad list of functions or features specific to text mining. | ATM, Automatic Term Recognition\| DCT, Document Clustering\| DCL, Document Classification\| DTM, Document Term Matrix\| IEX, Information Extraction\| IR, Information Retrieval\| NLP, Natural Language Processing\| TRV, Text Retrieval \| TCA, Text Categorization\| TCL, Text Cluster\| TSM, Text Summarization\| VIZ, Visualization\| WFA, Word Frequency Analysis
Help | Availability of instructions or other help documentation for use and installation of the tool | Any, link to help documentation or manual
Comments | Comments | Any
Registration | Is registration or an account required? | 0, No\| 1, Yes\| UC, Unclear