# Key Informant Comments on Specific Text-Mining Tools

Table D-1 Librarian comments on specific text-mining tools

Name | Comment^*^
AntConc | [Which terms are next to each other to identify phrases and words next to each other] I've recommending AntConc to some people designing and creating filters….if you really want to have a good objective way of creating a filter, you need more than just PubReMiner, then you need AntConc …If I do a search strategy, what I often use is proximity, so that words can be in close proximity within the certain set of words and that's one thing that I miss with the current text-mining programs. They cannot identify words that I could use in proximity. They only identify phrases and that's one thing that I would like to see in the future that maybe AntConc can solve [this problem] for me… [Problems with firewalls and software setting off local virus detection software, sometimes need to IT people to resolve the issue] AntConc is something that you download and you don't even need administrator rights, so you can just download it on [indiscernible] and save it anywhere, so no technical issues in it
EndNote | We use EndNote as well, particularly for the databases other than PubMed and MEDLINE where you don't have all the nice interfaces that people have built. The frequency analysis in EndNote we use for analyzing records from Embase and PsycINFO and so on. We can analyze the subject headings there [EndNote used to analyze keywords because they are easy to use. Shows frequency of keywords regardless of subheadings]
EPPI-Reviewer | [Eppi-Reviewer tools didn't take long [to learn how to use]]
GATE | For very complex questions, we've used the sort of more sophisticated software such as GATE Once you've got them loaded on your machine you're fine; I'm mean VOSviewer doesn't take long to load at all, even I can load that. But things like Mimir and GATE, it's not so much loading the software it's the sequence. You have to sort of bolt together a series of tasks within the software, and its knowing the order that you need to do those and the impact of each of the tasks. They're more of a tool box than a ready to run package, and you need to know the tools you want to select. They're not as user-friendly and intuitive as things like PubReMiner With GATE, I don't feel confident at all. I wouldn't drive that myself, I would leave it to somebody far more experienced who actually knew what they were doing
GoPubMed | More recently have been using software interfaces through PubMed such as PubReMiner and GoPubMed which again are frequency analysis packages to help us develop our strategies, but they perhaps are not as sophisticated as some text-mining packages GoPubMed looks nicer, but doesn't have a lot of the flexibility that I like in PubReMiner. It's nice for some of the nice graphics for showing the review team certain things and it's useful for graphical presentation of offered groupings, but it doesn't have a lot of the analyses that I actually value most
KNALIJ | PubReMiner and GoPubMed and KNALIJ and some of the other interfaces to PubMed, there people tend to do quick and clean searches or quick and dirty searches There are other packages out there, ones like KNALIJ….This is supposed to provide you with graphical presentations of batches of search results. It looks nice when it works, but it's very unpredictable about whether it'll actually work
Lingo3G | Lingo3G and Termine - good for quick overviews
PubReMiner | PubReMiner is easy to use and I've recommended it very frequently indeed. Also to lay people, the people that just started learning to create more systematic searches than just typing in four words in PubMed…. They can understand what you can gain out of PubReMiner I personally prefer PubReMiner compared to GoPubMed, because PubReMiner will give you an analysis of the words in the title and abstract. It also seems to give you a bit more control over the analyses you can undertake compared to GoPubMed, but GoPubMed now has …introduced sort of semantic analysis. It's not genuinely semantic analysis, but they've introduced some semantic analysis options as well which means it can do things that PubReMiner can't do PubReMiner will allow you to export the frequency tables as Excel spreadsheets, so that's really handy both for records and for sharing with people. Again, that's sort of a plus on the side of PubReMiner I think PubReMiner, GoPubMed, programs like that are very rapid to learn. I mean you could learn them in half an hour; I think most people can get to grips with them very quickly [PubReMiner is fast & easy to use. [It] has keyword limitations – can only analyze keywords together. Have to delete subheadings to get an accurate count. Is a good starting tool but doesn't do overrepresented terms] One of the downsides of … PubReMiner is [it is] only on PubMed, and we use MEDLINE … It's why I would not use it as often as I would if I used PubMed as my basic database
SimStat | Once you move into the areas of more sophisticated text-mining packages like GATE or Mimir or even VOSviewer and SimStat then you need a lot of time to get the best out of the packages
TerMine | Lingo3G and Termine - good for quick overviews
Text Mining Infrastructure in R | [Initially used R statistical program with text-mining module. It was free but it didn't have an interface so you needed to use a syntax language. Their colleagues had difficulty using this because they weren't programmers. They had syntax-related errors]
VOSviewer | Sometimes doing things like visual presentations, like using VOSviewer to show us the makeup of the literature visually can help us to see particular concepts that we're actually going to want to exclude later on …we've been working with a specialist in text-mining ….using more sophisticated text-mining software such as GATE and VOSviewer… These have been more serious text-mining packages that are not usually usable by most information professionals, so we've needed an intermediary to help us use that type of software I've used VOSviewer. It took me no time at all. Actually it took me probably a couple of hours reading the manual and then trying a few things out. In half a day I was feeling reasonably confident with VOSviewer You can export 10,000 results and load them very easily say into VOSviewer in a matter of moments just from exporting 10,000 records from PubMed in the PubMed format. Most of these sophisticated packages are built to take bibliographic records including abstracts in other fields
WordStat | [They switched to WordStat because it is focused just on text-mining. It isn't free, but it had a good user interface. Easier to use and fewer user errors. They could import from PubMed and calculate the overrepresentation]

* Comments appearing in square brackets are from workgroup member notes of the two KI interviews that were not recorded due to technical issues.