# Key Informant Interview Themes

Table C-1 Senior investigator/systematic review organization perspectives – interview themes

Themes | Exemplar Quote
Text-mining Overarching Comments
Promise of technology | To help them screen things that have several hundred thousand citations to screen because they were doing something on social activity or something like that and there was just no terms that capture it properly within the different databases, but they were able to use a custom algorithm for computer learning to train it as they moved along. And it was able to cut down the several hundred thousand citations to only about 15,000 they actually screened in the end There's a gazillion ways to use these types of tools for screening, for example. You can use them to prioritize the order in which you will fully, manually screen everything. You can use them as the sole screener, so, for example, you may decide to rely completely on them for the second half of the review. You can use them only during the update that happens after the draft. You can use them as an anomaly detection system, meaning that you have your double manual screening, and then you train the classifiers and see if there are other papers that have been excluded by the humans that should be seen at the second—someone should take a second look at them This new technological platform is clearly pointing to the direction where this kind of thing will go, not least because the volume of scientific information being produced around the world is growing so fast and so exponentially, our conventional methods of 20 years or more ago are rapidly becoming out of date…. In broad terms, this kind of approach seems to ask to be, if not the future, certainly an important part of the future, and it's something that needs to be grasped with both hands There's one very important, though, proviso. The conventional systems, as we all know, start from the notion that a priori you define your research question, a priori you've got a pretty good sense of what's in the literature, and a priori you've got a pretty good sense of the direction of travel within that literature. The possibilities of text-mining, when you're facing a much broader literature, where there is a need to break out of the conventional ways of thinking, it allows you to search iteratively into the literature, and it allows for the problem formulation to emerge eminently in the literature and really, it turns on its head. At least it has the possibility to turn on its head the conventional paradigm
Issues to be aware of | Some papers in this area have extraordinarily good results, but that's because they have favorable datasets, so that with a nice degree of distinction between the relevance and the irrelevant classes with lots of jargon you can get great results. So if somebody sort of saw that and said oh, well great, well I'm going to use that now….I think that would be a naïve way of using it….It's just the applicability of research findings from one context to another due to the situation in which these tools were developed and tested, how close is it to mine, what can I do to check to see how well the text-mining tools are performing in my situation rather than just assuming that they're going to perform the same in any situation, because they don't So your average systematic reviewer won't find these particularly easy to use in sort of like to their native form; you have to sort of integrate and put a front end on them to make them useful in reviews You have to know about the strengths and the limitations of those things so that you know how to optimally use them. You cannot use them blindly, you cannot be shoddy or silly when you're training them…and you cannot rely on them as an excuse to do sloppy work, because these things are trained based on the labels that you provide to them, so if you are sloppy, thinking that the algorithm will do it, you are training a very bad algorithm, and in the end it will backfire [the tool] does offer you cutoff points according to sort of probabilities, but using the rules-based approach, when we applied the rules, there were 15,000 records that met the rules that the rules said were relevant and I think the reviewers looked through all 15,000, but didn't look through the remaining [65,000] records. I'm sure in and amongst those other records there were probably relevant records that didn't meet the rules, but the reviewers didn't have enough time to go through all of those a well. That's the question, it's sort of the rules are great in a sense, but you do worry about the records that didn't meet the rules, because there's bound to be some that were probably highly relevant, but just didn't meet the rules
Why Did Your Organization Decide to Start Using Text-mining Software?
Process improvement | The reason was we were facing the big uphill task of undertaking two major reviews in areas where it was apparent that there was a very large amount of published material. That published material ranged over numerous different disciplines, had been generated using different methods and methodologies, and the conventional approach…would merely scratch the surface of what we wanted to know
In Which Step(s) of the Process Has Your Organization Used?
Searching | The information scientist, who puts together a lot of the searches, has used different tools to help think about search terms
Screening | The most heavy use we've made of it has been in terms of prioritizing the order in which citations are screened at the title and abstract stage, and we just routinely use text-mining for that now; it's sort of built into the system. We still haven't been able to let go of that usual sort of systematic reviewer obsession with looking at everything, so we still look at everything. But what we do is we prioritize the order, so we end up finding the most relevant citations very early in the screening process, which means we can then get on with the next stages of the review with those citations, retrieving the full text and screening them and getting on with the data abstraction and risk bias assessment and things, and that part gets moving while the screening is still going on the long tail of irrelevant studies
What Criteria Were Used to Determine Which Software Package(s) to Use?
No general theme emerged, the quotes presented show their respective thoughts on the topic | One is performance, I mean do they actually do what we need them to do, and the other criterion would be integratability, for want of a better word, so can we actually integrate the tool within existing web processes and tools. We use these tools basically to save time and labor, so they need to be integrated, but within our current process, otherwise they just add to the workloads I've picked up developing software in VBA for the simple purpose that as part of the budget we had no specific budget for software, so a lot of people will use things like for managing their citations like Distiller SR….Some of the people will use EPPI-Reviewer. Others will use what is available to them and what they're trained on, so if they are trained on for example creating an access database, they will use that I'm not sure that we did apply criteria….So it wasn't done on the basis of an option to appraise it, rather, if you like ongoing developmental work arising out of a project in another university and the natural colleagueship between different colleagues working in this new area
Does Utilizing Text-Mining Software Decrease or Increase the Length of Time to Complete the Review Process?
Systematic Review | We have not measured it formally in our shop
Scoping Review | It decreased it by eons. It would've been utterly impossible to undertake the scoping reviews that we did using conventional methods. The actual time spent in appraising the papers that were found and observing the linkages between them was probably undoubtedly less than a standard systematic reviewer would take using conventional search and find techniques. So very definitely, it's an aid to efficiency
How Well Did It Fit Within Your Existing Organizational Workflows?
Integration with systems and work flows | We've integrated it within the software which we use all the time, because then there are no problems in terms of data loss and maintaining data integrity and all that sort of thing. There's no real learning curve to use a lot of this, because it's all just sitting there in the space that everyone's used to using anyway. Yes, so it fits well. But it does mean that you have to do some upfront work to actually get the integration
What Were the Expenses Associated with Its Use in Terms of Staff Training, Software Costs, etc.?
Staff training | It's a difficult thing to answer for us, because people either have been involved with these things from the get-go or have been exposed to them for so long that it's—I don't know what the training cost would look like for someone who is using our tool de novo
Software | So there are costs associated with the tools and their implementation and their debugging and their maintenance, but it is very difficult to give you a breakdown
Were There or Are There Any Issues for Staff to Adapt to Its Usage?
Searching | After creating the printout of the frequency distribution, etc., I circulate it to the different staff members, especially the content experts to discuss the different terms and different option and I have not really had any sort of feeling of any issues, any negative issues with understanding the concepts of it
Screening | We jokingly refer to it here as extreme reviewing. In other words, the volume of stuff that you generate like this is potentially overwhelming. The people who were appraising the papers that were generated by this way really had to pull out all the stops to do it…. I don't know if it's so much extra work, but it produces a hump of work, or a peak of work, which the team has to go full throttle to keep up with
Were There or Are There Organizational or Technological Facilitators or Barriers to Implementation?
Facilitators | Once the decision was taken that that's what we were going to do by the senior members of the team, we did it. I don't think there were any significant implementation issues in terms of it taking time or anything like that. We've got a very committed staff who were very interested scientifically in how it would work, so they pulled out all the stops You clearly need good systems, and you need reliable systems….if you're trying to do this, or use this, in a system that was flaky, where connections didn't work, where systems were going down all the time, then it would be a major headache
Barriers | Although I'm a great enthusiast, and I see it as something helping university research and indeed systematic review organizations, there will, I think, be a bit of a war of attrition on the ground to resist some of this and to argue that machines can never do it as well as humans for all the reasons that people have been saying that since the invention of the spinning jenny and weaving cotton and so on Where the barriers came from was the specialist information scientists, who were the people who would help you to research strategies and all that kind of thing, who I think felt very threatened by text-mining's apparent ability to do what they spent their lives being training to do and they were professionally trained to do. I think that there was some considerable resistance to the research project from within the information specialists, information scientists, or at least some of them in the organization, who I think, with some justification actually, could see themselves being de-skilled by this technology
How Do You Evaluate the Value of Using Text-mining Software to the Review?
Need to do more formal evaluation in future | We haven't done a formal evaluation I think that we need a lot of work, empirical work in terms of eliciting metrics from experts in order to answer that question of evaluation
How Much Confidence Do You Have in the Results Generated by the Text-mining Tools Versus Your Previous Process?
No general theme emerged, the quotes presented show their respective thoughts on the topic | I think text-mining tends to work most effectively or historically has done so certainly in more clinical technical areas, because there's a nice little jargon for the text-mining to work off so it just finds that easier. I mean concepts such as healthy eating that kind of thing can be expressed in a number of different ways, and so the concepts of fuzzy area and it's more difficult for the text-mining to really sort of get a grip on what's going on All scientific findings of course are contingent, and ours are no different, and those generated by this method are no different. At the very least, I would say we had equal confidence in them from anything we've done before, and probably given the breadth of what we were able to look at, we may have even more confidence No one can guarantee you that these tools will find everything there is to find. There is always a risk, so if you use the tool the way that we have implemented it in our shop, which is to tell us in which order we will screen the literature. We still screen everything, but we start from the high, promising part and then move on to the other parts. You can trust it in the sense that you still complete the whole evidence base, but it has reordered the way that you do the full manual screening to make things move a bit faster….retrieving the full text and screening them and getting on with the data abstraction and risk of bias assessment and things…that part gets moving while the screening is still going on in the long tail of irrelevant studies
Do You Report Anything Differently Because You Used Text-mining in Your Review?
No general theme emerged, the quotes presented show the variety of reporting strategies | …report as transparently as we can what we did. It is challenging, because not many reviews have used text-mining for work production. It's quite easy to do it for prioritizing screening, you're just changing the order in which things are screened… we just speeded things up a bit for the later stages of the review. For other purposes, because you can't just easily say we've used this method, you have to go into quite a lot of detail exactly about what was done and there's no established method for any of this yet, so if you really wanted to report in proper detail about what you did you need to get into the specifics about what kind of feature selection you did, whether you stemmed words, whether you had a stop word list, which stop word list you used, and all that kind of thing potentially if you wanted to be properly transparent about it. At the moment there's no real sort of accepted way in which people do report this, so the danger is you end up writing a great long treatise on text-mining rather than the other methods of the review and the actual topic of the review itself… I don't think that we really know exactly how much detail we should be putting in reports I don't report anything differently So the only thing we might write is that we use [tool name deleted to preserve anonymity] for this kind of thing, to do the screening, but manage the logistics of the screening. If we use the machine learning algorithms for a double check, sometimes we may mention it as a quality control, or sometimes we may not mention it at all, but we have not been doing anything like that systematically

Table C-2 Librarian/review team member perspectives – interview theme

Themes | Exemplar Quote * **
Text-Mining: Overarching Comments
[perform a lot of research in a short amount of time and cannot be experts on all of the different questions, so text-mining is helpful…. new people perform equally in searching even if they are not as experienced] [Tool in developing the strategy rather than the only way to develop a search] I find that if you use a search strategy that's created in that way [using a filter] it's often too sensitive and too non-specific and that you find too much noise if you do it. So sometimes I still resort to doing my own traditional way in which I'm rather fast and that's one of the downsides why I don't use the text-mining a lot because I'm so fast with creating a search strategy The ability to search across disciplines, the ability to search across paradigms and methods, and the possibility of finding connections which you would only ever come across serendipitously in using all the conventional approaches that we do – [Senior Investigator/Systematic Review Organization] Some of the possibilities for translational facilities that can be done within it, its ability to search into the gray literature and beyond, and now into the blogosphere and all that kind of thing, offer ways of making what is otherwise utterly unmanageable knowledge, modern Tower of Babel into something that you could get at forensically. Also very importantly, to find connections in ways that you didn't think possible or wouldn't have occurred to you - [Senior Investigator/Systematic Review Organization]
Why Did You Begin Using Text-Mining Software to Develop Search Strategies?
Objectivity | Text-mining allows me to do that in a very objective way and to identify this information without spending too much time as an individual, but rather let the computer run the algorithm and figure that out for me
How Do You Utilize Text-Mining in Your Search Process?
Keyword / synonym tools | We will use text-mining to help us start to do the sort of scoping searches to find the search terms that might feature in the strategy. We use the text-mining to find synonyms, to find the subject headings, also to help us to see whether we can introduce new limits, so maybe geographic limits or whether there are particular literatures that we could try to safely exclude
When Using Text-Mining Software as Compared to Not Using It, Are There Gains or Losses in Efficiency (i.e., Amount of Time Needed to Develop) and/or Completeness of the Strategy?
Keyword / Synonym Tools | I think there are gains in efficiency, and there are gains in reliability. For example, if I'm running a quick search in PubReMiner, it makes me more confident that—I mean, PubReMiner can do frequency analysis and give me a list of terms from hundreds of records which I, personally, wouldn't have the time to look at. I couldn't look through 500 records and note down all the terms and make decisions about which ones are important for my strategy. PubReMiner gives me, for example, a nice table from which I can scan down and discuss with colleagues, and it gives me an objective feel for what those keywords are. It also lets me see the less frequently used terms which is going to be hard for me to spot if I'm just looking through a set of records by eye…Also by doing a series of small searches and getting to the point where I'm not finding extra terms, I can perhaps more quickly get to a sense of if I've got on top of the search terms that are available. That probably takes longer if I'm doing searches and looking through batches of records by eye
Filter Tools | To create a filter takes me maybe four hours if we have the gold standard strategy, so basically it often takes too long and I'm very happy with doing slightly less sensitive search strategies in a much shorter period than having to create filters for hours
Because Search Strategy Topics Vary Widely, Have You Noted Any Types of Questions for Which Text-Mining Software Works Particularly Well or Poorly?
Works well | I think it does work well for these horribly fuzzy topics and for the multi-question reviews where you're trying to save time by doing one big search and then interrogating it from several different angles….But for public health topics and nasty complex questions, I think text-mining sort of really does come into its own
Works poorly | I tend to think that it's not so useful when you've got a very clear cut question. A lot of our reviews are for single drugs for a very specific condition, and so for questions like that, text-mining is probably not helpful. You just don't need it. You have the drug name and some alternatives, and it's fairly straightforward to either just search for the drug name or the drug name in combination with the condition. For topics like that, from our perspective, you don't use text-mining, because it's very easy to develop a traditional search strategy.
How Do You Evaluate the Value of Using Text Mining?
No general theme emerged, the quotes presented show the variety of responses | I think there are possibly gains in efficiency there, but I've never actually measured it so I don't have any comparative information, but that does feel possibly more efficient than the usual way I'd go about finding terms by doing searches and looking at sets of records. If I'm looking at ten records, and deciding I've seen enough, you just get a chance to analyze more records than you could ever possibly scan by eye. That sort of makes me feel more confident, I guess, in those strategies I'm going to test out [Tried to look at different functions of the text-mining tool: word frequency, adjacency. Made the process longer but the search was more sensitive. … Exclusion analysis – a clear efficiency for later screening, for example a search in Medline on late diagnosis removed 4% of the studies (about 500 references) through using ‘NOT’] I guess what made us feel more reassured with the final review was that the review team also did lots of reference checking and looking at the cited references within relevant studies that they found. We sort of hoped that that would compensate in some way for the pragmatic decisions made elsewhere
How Much Confidence Do You Have in the Results Generated by the Text-Mining Tools Versus Your Previous Process?
Collaboration | I collaborate with an experienced text-mining specialist to make sure that I'm not worried about the quality of the end product… They're very complex packages. You need to know what you're doing, you need to know the algorithms that you're trying to achieve, and obviously, with expertise you can do things faster than if you don't know
Keyword / synonym tools | I feel more confident that we've found a variety of search terms that reflect the literature, and it also can highlight areas where literatures are more complex
Filter tools | In some ways it's an extension of a manual process and gives a level of assurance. It can be problematic because you can be misled by the corpus that you use to train the tool
Reporting Search Strategy Development in Systematic Reviews
Some text-mining tools reported but not others | I consider it to the whole process of text-mining to be more of a background search. Again, it will be the same as reviewing citations or hand searching includes the references of included searches. I don't particularly cite it as anything particular, because it is not an automation in and of itself, it's only an indication of where the human interaction can be best used….for example if I was using beta filtering or if I was using some sort of computer learning algorithm, so therefore there is an added sensitivity/specificity to it. The accuracy can differ depending on your algorithm and that could affect your overall results. I believe that would be something that is needed to be cited, but I don't see that the text-mining, per se, it would be no different than me saying for example before writing up a full search strategy, I did a rapid scoping of the literature or I did some quick and dirty searches. Those would not be identified as part of the official search that was done. I consider the text-mining to be in the similar sort of the same ballpark as that
Keyword/Synonym Text-Mining Tools or Filter-Type Tools KI Comments
How Did You Evaluate the Software to Determine Whether to Use It?
No general theme emerged. The quotes presented show the variety of responses | I tend to evaluate them by the types of facilities they offer and by the flexibility for altering the options that they offer and also for getting the output out [So many tools for different functions. Tried to characterize them and choose best tool for the purpose. Considered accessibility at her desktop. They use Lingo 3G through EPPI-Reviewer. Cost is an important factor. “Trialability” is important as well] I don't know if I ever really evaluated it. I don't remember when I heard about PubReMiner. It's a long time. I think when I started working six years ago, it already existed and my colleagues used it and that's why I started using it
Were There Any Loading or Technical Issues in Setting Up or Using the Software?
No issues | They're very straightforward, they're very reliable, and they tend to work every time
Issues | Problems with firewalls and software setting off local virus detection software, sometimes need to IT people to resolve the issue
Issues | The text-mining packages I use, it's sort of that wide range, from things that anybody can use through to things where we actually need someone to help us use them
How Long Did It Take to Learn the Software?
Keyword / synonym tools | I think PubReMiner, GoPubMed, programs like that are very rapid to learn. I mean you could learn them in half an hour; I think most people can get to grips with them very quickly. Once you move into the areas of more sophisticated text-mining packages like GATE or Mimir or even VOSviewer and SimStat then you need a lot of time to get the best out of the packages
How Do You Use the Output of the Tool?
Strategy evaluation | [Inform search strategy, take a subset and re-analyze text to see what you don't want]

* Comments appearing in square brackets are derived from workgroup member notes from the two KI interviews that were not recorded due to technical issues.

** Some comments included in this table are from senior investigators, [Senior Investigator/Systematic Review Organization] was added to each quote to clarify its source.