# Search Strategies

The following databases were searched:

1. SRC Methods Library
2. Inspec
3. LISA via ProQuest
4. Science Citation Index
5. Social Sciences Citation Index via Web of Knowledge
6. Library, Information Science & Technology Abstracts (LISTA) via EBSCO
7. HTAIvortal http://vortal.htai.org/?q=about/sure-info
8. Google Scholar
9. IEEE
10. Embase.com
11. PubMed (in process materials search)
12. PsycINFO
13. Cochrane Library

Other online sources searched were:

1. NacTEM website
2. Research Synthesis Methods TOC
3. PLOS text-mining collection: http://www.ploscollections.org/article/browseIssue.action?issue=info:doi/10.1371/issue.pcol.v01.i14
4. MillionShort.com
5. ACM digital library

The search syntax used in the database searches was tested in Embase.com. A sensitive search strategy was used in the title, abstract, and keyword fields (where available).

Text-mining | EMTREE ‘Machine learning’/exp Ultimate parent is ‘information processing’/exp | Literature mining Text mining Text analysis Machine NEAR/2 learning (document OR Text) NEAR/2 (classif* OR cluster* OR characteri* OR categoriz*) ‘support vector machine’ SVM Cluster NEAR/2 tool*
Text-mining | MeSH Exp artificial intelligence/ | Literature mining Text mining Text analysis Machine NEAR/2 learning (document OR Text) NEAR/2 (classif* OR cluster* OR characteri* OR categoriz*) ‘support vector machine’ SVM Cluster NEAR/2 tool*
Natural language processing | EMTREE ‘natural language processing’:de | ‘Natural language processing’ NLP ‘Term recognition’ ‘Word frequency analysis’
Natural language processing | MESH Included under artificial intelligence along with support vector machines | ‘Natural language processing’ NLP ‘Term recognition’ ‘Word frequency analysis’
| EMTREE ‘information retrieval’ | (information OR knowledge OR text) NEAR/2 visual* ‘objectively derived’ Summarization ‘text retrieval’ ‘visual data exploration’ automat* Semi NEAR/1 automat* Active learning Citation management Review management (article* OR citation* OR document*) NEAR/2 (identif* OR retrieval* OR screen*)
| MeSH Cluster analysis ‘Information storage and retrieval’
Specific tools | | ‘Abstrackr’ ‘Aquad’ ‘carrott2’ ‘cassandre’:ti,ab ‘coding analysis toolkit’ ‘computer aided textual markup & analysis’ ‘EPPI-Reviewer 4’ ‘FreeQDA’ ‘Konstanz Information Miner’ ‘KH Coder’ ‘LibreQDA’ ‘linguamatics’ ‘Machine Learning for Language Toolkit’ ‘medsum’ ‘NLM Medical Text Indexer’ ‘Pubhub’ ‘Pubnet’ ‘PubReMiner’ ‘QCAmap’ ‘QDA Miner Lite’ ‘Qigga’ ‘RQDA’ ‘SAS on demand’ ‘Semantic Features In Text’ ‘SIDER 2’ ‘Text analysis markup system’ ‘text mining infrastructure in R’ ‘Weft QDA’ ‘WordStat’ ‘Termine’ ‘Carrot Lingo 3G’ ‘Bibexcel’ ‘Voyant’
Systematic review | ‘systematic review (topic)’ ‘systematic review’ ‘meta analysis’ ‘meta analysis (topic)’ | systematic NEAR/2 review* (evidence OR research OR comprehensive) NEAR/2 (synthes* OR review) ‘Meta analysis’ Meta-analysis
Methods | | Method* Technique* Algorithm*

Limits: 2005-2015, English language

Set Number | Concept | Search Statement | # Identified
1 | Text-mining | ‘machine learning’/exp OR (machine NEAR/2 learning) | 71,160
2 | Text-mining | (‘literature’ OR ‘text’) NEAR/2 mining | 1,595
3 | Text-mining | (document OR text) NEAR/2 (classif* OR cluster* OR characteri* OR categoriz*) | 606
4 | Text-mining | ‘support vector machine’:de OR ‘support vector machine’ OR ‘SVM” | 11,271
5 | Text-mining | Cluster* NEAR/2 tool* | 248
6 | Text-mining | #1 OR #2 OR #3 OR #4 OR #5 | 75,134
7 | Natural language processing | ‘natural language processing’:de OR ‘natural language processing’ OR ‘NLP’ OR ‘term recognition’ OR ‘word frequency analysis’ | 2,876
8 | Combine sets | #6 OR #7 | 77,011
9 | Potential uses | ‘information retrieval’:de | 16,708
10 | Potential uses | (information OR knowledge OR text) NEAR/2 visual* | 7,341
11 | Potential uses | ‘objectively derived’ OR summarization OR ‘text retrieval’ OR ‘visual data exploration’ OR ‘visual data representation’ OR ‘data abstraction’ | 1,428
12 | Potential uses | Automat* OR (semi NEAR/2 automat*) | 136,711
13 | Potential uses | (citation OR review) NEAR/2 manag* | 6,575
14 | Potential uses | (article* OR citation* OR document*) NEAR/2 (identif* OR retrieval* OR screen*) | 13,197
15 | Potential uses | #9 OR #10 OR #11 OR #12 OR #13 OR #14 | 177,247
16 | Systematic reviews | ‘systematic review’:de OR ‘systematic review (topic)’:de | 94,565
17 | Systematic reviews | Systematic NEAR/2 review* | 123,057
18 | Systematic reviews | (evidence OR research OR comprehensive OR critical OR Cochrane) NEAR/2 (synthes* OR review*) | 70,436
19 | Systematic reviews | ‘meta analysis’:de OR ‘meta analysis (topic)’:de OR (meta NEAR/1 analy*) | 109,864
20 | Combine sets | #16 OR #17 OR #18 OR #19 | 225,345
21 | Limiting concepts | #20 AND (method* OR technique* OR algorithm*) | 123,113
22 | Combine sets | #8 AND #15 AND #21 | 140
23 | Specific programs | ‘Abstrackr’ OR ‘Aquad’ OR ‘carrott2’ OR ‘cassandre’:ti,ab OR ‘coding analysis toolkit’ OR ‘computer aided textual markup & analysis’ OR ‘EPPI-Reviewer 4’ OR ‘FreeQDA’ OR ‘Konstanz Information Miner’ OR ‘KH Coder’ OR ‘LibreQDA’ OR ‘linguamatics’ OR ‘Machine Learning for Language Toolkit’ OR ‘medsum’ OR ‘NLM Medical Text Indexer’ OR ‘Pubhub’ OR ‘Pubnet’ OR ‘PubReMiner’ OR ‘QCAmap’ OR ‘QDA Miner Lite’ OR ‘Qigga’ OR ‘RQDA’ OR ‘SAS on demand’ OR ‘Semantic Features In Text’ OR ‘SIDER 2’ OR ‘Text analysis markup system’ OR ‘text mining infrastructure in R’ OR ‘Weft QDA’ OR ‘WordStat’ OR ‘Termine’ OR ‘Carrot Lingo 3G’ OR ‘Bibexcel’ OR ‘Voyant’ | 213
24 | Combine sets | #21 AND #23 | 6
25 | Combine sets | #22 OR #24 | 146