# Results

## Use of Continuous Outcomes in AHRQ Systematic Reviews

Between 1999 and June 2012, a total of 263 AHRQ systematic reviews were conducted and 247 reviews evaluated at least one continuous outcome. Among these reviews, 133 (50.6%) included a meta-analysis and 74 (28.1%) included a meta-analysis of continuous outcomes, which was 55.6 percent among those with a meta-analysis conducted. However, only four reviews explicitly mentioned the issue of baseline imbalance. In particular, one review used meta-regression to adjust for baseline imbalance; one review stated that meta-regression was not used, citing concerns for ecological fallacy. The other two reviews only combined studies in the presence of baseline imbalance when mean change score from baseline could be used in the meta-analysis, though they failed to recognize that using change score did not address the problem of baseline imbalance.

Among the 74 reviews including a meta-analysis of continuous outcomes, 41 (55.4%) used MD exclusively, 21 (28.4%) used SMD exclusively, 9 (12.2%) used both MD and SMD, 2 (2.7%) used percent change and 1 (1.4%) used both MD and percent change. In addition, 16 of the 74 reviews (21.6%) provided some description on how to handling missing standard deviation, 5 (6.8%) described how to handle missing correlation between baseline and followup point, and 4 reviews (5.4%) mentioned using median to approximate mean values (for skewed data).

A total of 63 CERs were conducted between 2005 to June 2012, and 19 of them conducted a meta-analysis using mean difference. Six CERs were selected for evaluation of use of the change score versus the followup score, and other CERs were excluded due to duplicate reviews, duplicate outcomes, small number of studies (<3), inclusion of variables that were not measured at both baseline and followup (e.g., birth weight, length of stay), or lack of forest plots to identify which studies and data were included in the meta-analyses. A total of 63 meta-analyses from six CERs15-20 were included in the following evaluation.

## Impact of the Mean Difference Estimates

One CER15 reported using both change score and followup score to estimate mean difference and the others16-20 reported using change score. These meta-analyses included 156 trials, among which 58 trials (37.2%) reported using an ANCOVA model, though only 16 trials reported at least one ANCOVA estimate, less than 30 percent of trials that used an ANCOVA model. Comparisons of results using change score versus followup score were shown in Table 2 and Table 3, though Table 2 and Table 3 only included results based on Dersimonian-Laird (DL) method and profile likelihood (PL) method and Table 3 only presented meta-analyses with discrepancy in conclusion or significant baseline difference. The complete results for all analyses based on all six random effects estimates were shown in appendixes A and B.

Table 2 Comparison of combined mean differences using change score and endpoints (treatment versus control) based on PL and DL methods

Comparative Effectiveness Review | Outcome: Comparison (Group #1 vs. Group #2) | Number of Studies (N) Group #1 and Group #2 Total Sample Size (Min–Max) | Baseline Difference (95% CI) | Difference in Change Score (95% CI) | Difference in Endpoint Score (95% CI) | Percentage Difference in Combined Estimates
Pain Management Interventions for Hip Fracture 15 | Acute pain: skin traction vs. no traction | 13 studies #1: 568 (30–166) #2: 662 (34–151) | PL: -0.300 (-0.812, 0.260) DL: -0.281 (-0.843, 0.280) I^2^ = 77.2%, P < 0.001 | PL: 0.432 (-0.137, 0.997) DL: 0.431 (-0.125, 0.987) I^2^ = 76.5%, P < 0.001 | PL: 0.115 (-0.332, 0.617) DL: 0.122 (-0.316, 0.561) I^2^ = 63.2%, P = 0.008 | PL: 73% DL: 72%
Diagnosis and Treatment of Obstructive Sleep Apnea in Adults 16 | Apnea-Hypopnea Index: CPAP vs. control | 6 studies #1: 177 (12–66) #2: 159 (12–59) | PL: 2.208 (-3.442, 9.009) DL: 2.532 (-2.798, 7.862) I^2^ = 64.7%, P = 0.015 | PL: -27.022 (-41.194, -13.631) DL: -27.051 (-38.909, -15.193) I^2^ = 93.3%, P < 0.001 | PL: -24.176 (-36.050, -13.153) DL: -24.134 (-33.599, -14.669) I^2^ = 91.9%, P < 0.001 | PL: -11% DL: -11%
Diagnosis and Treatment of Obstructive Sleep Apnea in Adults 16 | Epworth Sleepiness Scale: CPAP vs. control | 7 studies #1: 448 (19–178) #2: 398 (21–181) | PL: -0.015 (-0.523, 0.494) DL: -0.015 (-0.435, 0.406) I^2^ = 0%, P = 0.805 | PL: -2.684 (-4.311, -1.169) DL: -2.714 (-4.274, -1.155) I^2^ = 84.3%, P < 0.001 | PL: -2.325 (-3.645, -1.220) DL: -2.371 -3.415, -1.327) I^2^ = 54.2%, P = 0.042 | PL: -13% DL: -13%
Diagnosis and Treatment of Obstructive Sleep Apnea in Adults 16 | Apnea-Hypopnea Index: CPAP vs. sham CPAP | 8 studies #1: 163 (15–27) #2: 149 (10–29) | PL: 7.161 (1.241, 13.088)^a^ DL: 7.161 (1.260, 13.063)^a^ I^2^ = 0%, P = 0.920 | PL: -45.634 (-58.285, -34.180) DL: -45.891 (-57.534, -34.249) I^2^ = 70.9%, P = 0.001 | PL: -40.495 (-52.287, -29.403) DL: -40.690 (-52.073, -29.307) I^2^ = 82.4%, P < 0.001 | PL: -11% DL: -11%
Diagnosis and Treatment of Obstructive Sleep Apnea in Adults 16 | Epworth Sleepiness Scale: CPAP vs. sham CPAP | 11 studies #1: 293 (16–52) #2: 291 16–49) | PL: 0.309 (-0.263, 0.876) DL: 0.309 (-0.258, 0.876) I^2^ = 0%, P = 0.920 | PL: -2.684 (-4.345, -1.033) DL: -2.688 (-4.399, -0.977) I^2^ = 83.4%, P < 0.001 | PL: -2.555 (-4.197, -0.918) DL: -2.556 (-4.209, -0.904) I^2^ = 82.2%, P < 0.001 | DL: -5% PL: -5%
Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults 17 | Depressive severity: rTMS vs. sham (condition = Tier 1, MDD) | 8 studies #1: 116 (7–32) #2: 102 (5–31) | PL: 0.638 (-0.530, 2.671) DL: 0.638 (-0.460, 1.736) I^2^ = 0%, P = 0.520 | PL: -5.442 (-7.792, -2.672)^a^ DL: -5.394 (-7.764, -3.025)^a^ I^2^ = 43.9%, P = 0.086 | PL: -3.068 (-6.171, 0.371)^a^ DL: -2.898 (-6.508, 0.711)^a^ I^2^ = 79.2%, P < 0.001 | PL: -44% DL: -46%
Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults 17 | Depressive severity: rTMS vs. sham (condition = Tier 1) | 11 studies #1: 197 (7–36) #2: 149 (5–31) | PL: 0.680 (-0.374, 2.276) DL: 0.680 (-0.276, 1.636) I^2^ = 0%, P = 0.452 | PL: -5.690 (-7.813, -3.478) DL: -5.672 (-7.784, -3.561) I^2^ = 54.4%, P = 0.015 | PL: -3.906 (-6.284, -1.401) DL: -3.841 (-6.482, -1.199) I^2^ = 73.6%, P < 0.001 | PL: -31% DL: 32%
Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults 17 | Depressive severity: rTMS vs. sham (condition = Tier 1&2, MDD) | 12 studies #1: 374 (7–155) #2: 364 (5–146) | PL: -0.013 (-0.595, 0.764) DL: -0.013 (-0.569, 0.544) I^2^ = 0%, P = 0.688 | PL: -4.719 (-7.097, -2.319) DL: -4.714 (-7.126, -2.301) I^2^ = 80.4%, P < 0.001 | PL: -3.441 (-5.943, -0.802) DL: -3.436 (-5.83, -1.041) I^2^ = 79.3%, P < 0.001 | PL: -27% DL: -27%
Screening, Behavioral Counseling, and Referral in Primary Care To Reduce Alcohol Misuse 20 | Drinks/week: BCI vs. control (adults, 6 months) | 11 studies #1: 1547 (39-353) #2: 1556 (32-376) | PL: 0.613 (-0.247, 1.606) DL: 0.613 (-0.229, 1.456) I^2^ = 0%, P = 0.490 | PL: -3.121 (-4.255, -2.310) DL: -3.228 (-4.214, -2.242) I^2^ =13.9%, P = 0.311 | PL: -2.504 (-4.037, -1.210) DL: -2.593 (-4.063, -1.123) I^2^ =46.3%, P = 0.046 | PL: -20% DL: -20%
Screening, Behavioral Counseling, and Referral in Primary Care To Reduce Alcohol Misuse 20 | Drinks/week: BCI vs. control (adults, 12 months) | 13 studies #1: 2088 (33-371) #2: 2012 (39-381) | PL: 0.455 (-0.403, 1.282) DL: 0.455 (-0.364, 1.274) I^2^ = 0%, P = 0.649 | PL: -3.700 (-4.641, -2.805) DL: -3.718 (-4.760, -2.677) I^2^ =16.9%, P = 0.274 | PL: -2.920 (-4.912, -0.800) DL: -2.936 (-4.601, -1.272) I^2^ =57.2%, P = 0.005 | PL: -21% DL: -21%

a Significant baseline difference or discrepancy in conclusion.

BCI = behavioral counseling intervention; CI = confidence interval; CPAP = continuous positive airway pressure; DL = DerSimonian-Laird random-effects method; MDD = major depressive disorderPL = profile likelihood method; rTMS = repetitive transcranial magnetic stimulation.

Table 3 Discrepancy in comparison of combined mean differences using change score and endpoints (comparison between different treatments) based on PL and DL methods

Comparative Effectiveness Review | Outcome Comparison (Group #1 vs. Group #2) | Number of Studies (N) Group #1 and Group #2 Total Sample Size (Min–Max) | Baseline Difference (95% CI) | Difference in Change Score (95% CI) | Difference in Endpoint Score (95% CI)
Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression: An Update of the 2007 Comparative Effectiveness Review 18 | MADRS: citalopram vs. escitalopram | 6 studies #1: 939 (125–214) #2: 932 (108–241) | PL: 0.178 (-0.341, 0.646) DL: 0.171 (-0.283, 0.625) I^2^ = 12.7%, P = 0.333 | PL: 2.108 (0.078, 4.008)^a^ DL: 2.077 (0.174, 3.979) I^2^ = 67.8%, P = 0.008 | PL: 2.258 (-0.073, 4.430)^a^ DL: 2.221 (0.060, 4.383) I^2^ = 68.7%, P = 0.007
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HbA1c: metformin vs. thiazolidinediones | 14 studies #1: 1132 (13–501) #2: 1127 (14–499) | PL: -0.017 (-0.097, 0.062) DL: -0.017 (-0.109, 0.074) I^2^ = 9.7%, P = 0.347 | PL: -0.105 (-0.188, -0.025)^a^ DL: -0.106 (-0.214, 0.003) I^2^ = 24.9%, P = 0.186 | PL: -0.054 (-0.186, 0.103)^a^ DL: -0.053 (-0.182, 0.077) I^2^ = 58.0%, P = 0.003
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HbA1c: metformin vs. metformin and thiazolidinediones | 11 studies #1: 1428 (34–277) #2: 1688 (60–296) | PL: -0.160 (-0.283, -0.034)^a^ DL: -0.158 (-0.290, -0.027)^a^ I^2^ = 69.6%, P = 0.001 | PL: 0.633 (0.432, 0.854) DL: 0.635 (0.437, 0.832) I^2^ = 85.5%, P < 0.001 | PL: 0.503 (0.280, 0.733) DL: 0.506 (0.268, 0.744) I^2^ = 93.4%, P < 0.001
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HbA1c: metformin and Sulfonylureas vs. Thiazolidinediones and Sulfonylureas | 6 studies #1: 847 (37–320) #2: 871 (34–319) | PL: -0.123 (-0.238, 0.008) DL: -0.126 (-0.217, -0.034)^a^ I^2^ = 8.3%, P = 0.363 | PL: -0.050 (-0.151, 0.069)^a^ DL: -0.050 (-0.148, 0.047)^a^ I^2^ = 0%, P = 0.628 | PL: -0.165 (-0.262, -0.061)^a^ DL: -0.165 (-0.262, -0.068)^a^ I^2^ = 30.7%, P = 0.205
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: metformin vs. sulfonylureas (studies < 24 weeks in duration) | 8 studies #1: 718 (21–164) #2: 797 (18–161) | PL: 1.669 (0.115, 3.208)^a^ DL: 1.669 (0.163, 3.175)^a^ I^2^ = 0%, P = 0.939 | PL: -2.240 (-2.747, -1.792)^a^ DL: -2.234 (-2.640, -1.828)^a^ I^2^ = 2.8%, P = 0.408 | PL: -0.634 (-2.144, 0.852)^a^ DL: -0.634 (-2.118, 0.850)^a^ I^2^ = 0%, P = 0.883
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: metformin and sulfonylureas vs. combination thiazolidinediones and sulfonylureas. | 4 studies #1: 653 (37–320) #2: 646 (34–319) | PL: 1.746 (-2.856, 6.117) DL: 1.672 (-2.815, 6.160) I^2^ = 87.5%, P < 0.001 | PL: -2.689 (-3.840, -1.550)^a^ DL: -2.689 (-3.747, -1.631)^a^ I^2^ = 78.1%, P = 0.003 | PL: -0.935 (-6.105, 3.972)^a^ DL: -1.038 (-6.510, 4.434)^a^ I^2^ = 90.8%, P < 0.001
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | LDL: metformin vs. rosiglitazone | 6 studies #1: 198 ( 9–117) #2: 213 (14–128) | PL: 2.100 (-4.188, 8.886) DL: 2.100 (-3.960, 8.159) I^2^ = 0.0%, P = 0.682 | PL: -12.535 (-22.237, -5.876)^a^ DL: -13.263 (-20.553, -5.974) I^2^ = 58.0%, P = 0.036 | PL: -14.009 (-29.491, 2.268)^a^ DL: -13.944 (-27.561, -0.327) I^2^ = 65.7%, P = 0.012
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: metformin vs. rosiglitazone | 6 studies #1: 198 (9–117) #2: 213 (14–128) | PL: Does not converge DL: -2.408 (-4.400, -0.416)^a^ I^2^ = 0.0%, P = 0.673 | PL: -0.595 (-1.658, 2.319) DL: -0.052 (-1.877, 1.774) I^2^ = 42.6%, P = 0.121 | PL: 0.445 (-2.983, 3.832) DL: 0.445 (-2.941, 3.831) I^2^ = 0%, P = 0.922
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: metformin vs. DPP–4 inhibitors | 3 studies #1: 913 (241–427) #2: 791 (95–440) | PL: 0.711 (-0.271, 1.673) DL: 0.711 (-0.217, 1.639) I^2^ = 0.0%, P = 0. 787 | PL: 1.432 (-0.004, 3.251)^a^ DL: 1.514 (0.132, 2.897) I^2^ = 34.1%, P = 0.219 | PL: 2.112 (0.705, 3.899)^a^ DL: 2.199 (0.814, 3.584) I^2^ = 33.9%, P = 0.220
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: pioglitazone vs. sulfonylurea | 6 studies #1: 304 (17–91) #2: 311 (18–109) | PL: 1.375 (-0.020, 2.695) DL: 1.375 (0.074, 2.675)^a^ I^2^ = 0.0%, P = 0. 706 | PL: 5.295 (3.480, 6.964) DL: 5.278 (3.472, 7.084) I^2^ = 43.3%, P = 0.117 | PL: 6.369 (3.528, 8.853) DL: 6.325 (4.021, 8.630) I^2^ = 60.5%, P = 0.027
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Triglycerides: metformin vs. sulfonylureas | 11 studies #1: 812 (19–210) #2: 858 (18–209) | PL: 17.186 (-2.503, 23.406) DL: 17.186 (10.965, 23.406)^a^ I^2^ = 0.0%, P = 0. 500 | PL: -17.217 (-28.683, -4.876)^a^ DL: -17.217 (-28.684, -5.750)^a^ I^2^ = 0.0%, P = 0.669 | PL: -5.847 (-23.606, 10.612)^a^ DL: -6.444 (-24.536, 11.648)^a^ I^2^ = 67.9%, P = 0.001

a Significant baseline difference or discrepancy in conclusion.

CI = confidence interval; DL = DerSimonian-Laird random-effects method; DPP-4 = Dipeptidyl peptidase-4; HbA1c = hemoglobin A1c/glycated hemoglobin; HDL = high-density lipoprotein; LDL = low-density lipoprotein; MADRS = Montgomery-Asberg Depression Rating Scale; PL = profile likelihood method.

Based on the DL method, using change score versus followup score led to 5 out of the 63 meta-analysis (7.9%) showing discrepancy in conclusions; and based on the PL method, 9 (14.3%) showed discrepancy in conclusions (see bolded values in tables 2 and 3; only discrepancies based on DL and PL methods are bolded). In general, using the change score is more likely to show a significant difference in effects between interventions. For the five meta-analyses showing discrepancies using DL method, four showed significant differences when using change score, and one showed significant result when using the followup score. For the nine meta-analyses showing discrepancies using PL method, seven showed significant differences when using change score and two showed significant differences when using the followup score. Therefore, though not necessarily more accurate, using the followup score is more likely to produce conservative results based on these comparisons.

Compared with the DL method, estimates based on the maximum likelihood (ML) and restricted maximum likelihood (REML) methods tended to have narrower 95 percent confidence intervals (CIs), though the REML method sometimes provided more conservative 95 percent CIs. The permutation (PE) method worked only when there were at least six studies in a meta-analysis and provided much wider, and often unrealistically wide 95 percent CIs. In addition, the PE 95 percent CIs are often practically invalid with lower bounds like -4.8e+15 when there were only six studies. The Knapp-Hartung modification (KH) produced narrower 95 percent CIs compared to the PE method, but wider 95 percent CIs than others. Using ML method led to discrepancy in conclusions in six meta-analyses and the impact of change score versus followup score using the ML method is largely similar to using the DL method. Interestingly, the impact using the REML method is similar to using the PL method with eight meta-analyses showing discrepancy in conclusions (see italicized values on appendixes A and B). Estimates from PE method are not available in many cases, and the 95 percent CIs of PE method, when present, are too wide to make meaningful comparisons. Lastly, using the KH modification led to a discrepancy in conclusions in ten meta-analyses, the highest among the different methods, seven showed significant differences when using the change score, and three showed significant differences when using the followup score.

Sensitivity analyses using ANCOVA estimates (whenever they were available) did not change the results, which may be partly because only a few ANCOVA estimates were reported. Sensitivity analyses assuming different values of correlation between baseline and followup from 0.3 to 0.7 also generally provided the same results.

Additional details of the results are provided below, with results stratified by the comparison of intervention versus control and the comparison between interventions.

### Meta-Analysis of Intervention Versus Control

Ten meta-analyses from four CERs15-17,20 compared active intervention versus control or usual care on pain, Apnea-Hypopnea Index, Epworth Sleepiness Scale, depression, and alcohol use. These meta-analyses included 5 to 13 studies and 218 to 4,100 patients (Table 2).

When the baseline imbalance occurs by chance, the combined baseline difference across included studies should be close to zero. The combined baseline differences indicated significant imbalance (different from zero) in 1 of the 10 meta-analyses (Apnea-Hypopnea Index, continuous positive airway pressure [CPAP] vs. sham CPAP), and the combined mean differences using change score versus endpoint also led to discrepancy in conclusions in another meta-analysis (depressive severity, repetitive transcranial magnetic stimulation vs. sham for condition = Tier1, major depressive disorder). Therefore the significant baseline imbalance does not necessarily coincide with the discrepancy in conclusions. For this particular case (Apnea-Hypopnea Index, CPAP vs. sham CPAP), the magnitude of the mean difference is large and so the baseline difference only led to qualitative differences in the combined mean difference.

For the one meta-analysis showing discrepancy in conclusions, using the change score showed significant results based on both PL and DL methods (as well as REML and the KH modification method, Appendix A). However, more interestingly, except for one meta-analysis (acute pain, skin traction vs. no traction), the combined mean difference using change score consistently showed a larger intervention effect than the combined mean difference using endpoint score, by a considerable amount. Compared with the combined mean difference using change score, the combined mean difference using endpoint score showed an intervention effect of about 20 percent smaller on average, ranging from 5 percent to more than 40 percent.

For these comparisons, the magnitude of heterogeneity and the results of testing heterogeneity were generally similar between the two estimates.

### Meta-Analysis of Comparison Between Interventions

Fifty-three meta-analyses from three CERs16,18,19 compared outcomes between active interventions. Most (50) of these are from one CER19 comparing the various oral diabetes medications for adults with type 2 diabetes on weight, A1C, and lipid variables. The other three meta-analyses compared sleepiness16 and depression18 variables. These meta-analyses included 3 to 17 studies and 215 to 3,252 patients (Table 3).

Based on the DL method, using the change score versus the followup score led to 4 out of the 53 meta-analyses (7.5%) showing discrepancy in conclusions, and 3 showed significant results when using the change score. At the same time, significant baseline differences occurred in six meta-analyses (highlighted in Table 3), and three meta-analyses showed both significant baseline difference and discrepancy in conclusions. Based on the PL method, eight (15.1%) showed discrepancy in conclusions, with six showing significant results when using the change score and two showing significant results using the followup score. Only two meta-analyses showed significant baseline differences using the PL method, and one is associated with discrepancy in conclusions. On the other hand, not all studies in each meta-analysis provided data to meta-analyze baseline difference (though most did), so the results of baseline difference may not fully reflect the baseline distribution of the included studies. We did not calculate the percent difference between the two combined mean differences since there was no clearly defined (active) control for these comparisons.

For most meta-analyses, the magnitude of heterogeneity and the results of testing heterogeneity were comparable between the two measures. When heterogeneity showed a difference between the two estimates, there was no clear pattern of one estimate having more heterogeneity than the other. In the presence of a discrepancy in conclusions, the estimate with significant results did not necessarily have less heterogeneity among studies (lower I^2^ values). In addition, the number of individual studies included in meta-analyses with discrepant conclusions varied from 3 to 14, the total number of patients varied from a few hundred to a few thousand, and the studies reported various outcomes (depressive severity, Montgomery-Asberg Depression Rating Scale, HbA1C, weight, lipid variables). These meta-analyses revealed no clear common characteristics.