# References

1 Senn S. Testing for baseline balance in clinical trials. Stat Med. Sep. 15. 1994;13(17):1715-26. [pmid: 7997705].
2 Crager MR. Analysis of covariance in parallel-group clinical trials with pretreatment baselines. Biometrics. Dec. 1987;43(4):895-901. [pmid: 3427174].
3 Senn S. Change from baseline and analysis of covariance revisited. Stat Med. Dec. 30. 2006;25(24):4334-44. [pmid: 16921578].
4 Rosenberger W, Lachin J, editors. Randomization in Clinical Trials: Theory and Practice. New York. Wiley. 2002.
5 Schulz KF, Grimes DA. Allocation concealment in randomised trials: defending against deciphering. Lancet. 2002;359(9306):614-8. [pmid: 11867132].
6 Hewitt CE, Kumaravel B, Dumville JC, et al. Assessing the impact of attrition in randomized controlled trials. J Clin Epidemiol. Nov. 2010;63(11):1264-70. [pmid: 20573482].
7 Hartling L, Hamm MP, Fernandes RM, et al. Quantifying bias in randomized controlled trials in child health: a meta-epidemiological study. PLoS One. 2014;9(2):e88008. [pmid: 24505351].
8 Vickers AJ, Altman DG. Statistics notes: Analysing controlled trials with baseline and follow up measurements. BMJ. 2001;323:1123-4. [pmid: 11701584].
9 da Costa BR, Nuesch E, Rutjes AW, et al. Combining follow-up and change data is valid in meta-analyses of continuous outcomes: a meta-epidemiological study. J Clin Epidemiol. Aug. 2013;66(8):847-55. [pmid: 23747228].
10 Riley RD, Kauser I, Bland M, et al. Meta-analysis of randomised trials with a continuous outcome according to baseline imbalance and availability of individual participant data. Stat Med. Jul. 20. 2013;32(16):2747-66. [pmid: 23303608].
11 Trowman R, Dumville JC, Torgerson DJ, et al. The impact of trial baseline imbalances should be considered in systematic reviews: a methodological case study. J Clin Epidemiol. Dec. 2007;60(12):1229-33. [pmid: 17998076].
12 Fu R, Vandermeer BW, Shamliyan TA, et al. Handling Continuous Outcomes in Quantitative Synthesis. Methods Guide for Comparative Effectiveness Reviews. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 13-EHC103-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2013. [pmid: 24006546]. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
13 Cornell JE, Mulrow CD, Localio R, et al. Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. Feb. 18. 2014;160(4):267-70. [pmid: 24727843].
14 Evidence-based Practice Center Reports by Year. Rockville, MD. Agency for Healthcare Research and Quality. 2014. www.ahrq.gov/research/findings/evidence-based-reports/year/index.html. April 1, 2015.
15 Abou-Setta AM, Beaupre LA, Jones CA, et al. Pain Management Interventions for Hip Fracture. Comparative Effectiveness Review No. 30. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-02-0023.) AHRQ Publication No. 11-EHC022-EF. Rockville, MD. Agency for Healthcare Research and Quality. May. 2011. [pmid: 21938799]. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
16 Balk EM, Moorthy D, Obadan NO, et al. Diagnosis and Treatment of Obstructive Sleep Apnea in Adults. Comparative Effectiveness Review No. 32. (Prepared by Tufts Evidence-based Practice Center under Contract No. 290-2007-10055-1). AHRQ Publication No. 11-EHC052-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2011. [pmid: 21977519]. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
17 Gaynes BN, Lux L, Lloyd S, et al. Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults. Comparative Effectiveness Review No. 33. (Prepared by RTI International-University of North Carolina (RTI-UNC) Evidence-based Practice Center under Contract No. 290-02-0016I.) AHRQ Publication No. 11-EHC056-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2011. [pmid: 22091472]. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
18 Gartlehner G, Hansen RA, Morgan LC, et al. Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression: An Update of the 2007 Comparative Effectiveness Review. (Prepared by the RTI International–University of North Carolina Evidence-based Practice Center, Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC012-EF. Rockville, MD. Agency for Healthcare Research and Quality. December. 2011. [pmid: 22299185]. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
19 Bennett WL, Wilson LM, Bolen S, et al. Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update. Comparative Effectiveness Review No. 27. (Prepared by Johns Hopkins University Evidence-based Practice Center under Contract No. 290-02-0018.) AHRQ Publication No. 11-EHC038-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011. [pmid: 21735563]. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
20 Jonas DE, Garbutt JC, Brown JM, et al. Screening, Behavioral Counseling, and Referral in Primary Care to Reduce Alcohol Misuse. Comparative Effectiveness Review No. 64. Prepared by the RTI International–University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC055-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2012. [pmid: 22876371]. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
21 Higgins JP, White IR, Anzures-Cabrera J. Meta-analysis of skewed data: combining results reported on log-transformed or raw scales. Stat Med. Dec. 20. 2008;27(29):6072-92. [pmid: 18800342].
22 Roberts C, Torgerson DJ. Understanding controlled trials: baseline imbalance in randomised controlled trials. BMJ. Jul. 17. 1999;319(7203):185. [pmid: 10406763].
23 Begg CB. Suspended judgment. Significance tests of covariate imbalance in clinical trials. Control Clin Trials. Aug. 1990;11(4):223-5. [pmid: 2171874].
24 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. Sep. 15. 2003;22(17):2693-710. [pmid: 12939780].
25 Kontopantelis E, Reeves D. Performance of statistical methods for meta-analysis when true study effects are non-normally distributed: A simulation study. Stat Methods Med Res. Aug. 2012;21(4):409-26. [pmid: 21148194].
26 Kontopantelis E, Reeves D. Performance of statistical methods for meta-analysis when true study effects are non-normally distributed: a comparison between DerSimonian-Laird and restricted maximum likelihood. Stat Methods Med Res. Dec. 2012;21(6):657-9. [pmid: 23171971].
27 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
28 IntHout J, Ioannidis JP, Borm GF. The Hartung-Knapp-Sidik-Jonkman method for random effects meta-analysis is straightforward and considerably outperforms the standard DerSimonian-Laird method. BMC Med Res Methodol. 2014;14:25. [pmid: 24548571].
29 Senn S. Baseline distribution and conditional size. J Biopharm Stat. Sep. 1993;3(2):265-76. [pmid: 8220409].
30 Wright DB. Comparing groups in a before-after design: when t test and ANCOVA produce different results. Br J Educ Psychol. Sep. 2006;76(Pt 3):663-75. [pmid: 16953968].