# Methods

## Selection and Abstraction of Data

We first reviewed all systematic reviews the Agency for Healthcare Research and Quality (AHRQ) published from 1999 to June 2012^14^, including the general reviews conducted from 1999 to 2011 and the comparative effectiveness reviews (CERs) the AHRQ Evidence-based Practice Center Program conducted from 2005 to June 2012. For each review, we abstracted data on whether continuous outcome and meta-analysis were used, the effect measure of continuous outcomes (mean difference [MD] vs. standardized mean difference [SMD]), and meta-analysis methods. The use of MD versus SMD typically depends on the scales of the included outcomes. When the reported outcomes use the same scale, MD could be used; otherwise, SMD should be used. Additional abstracted information included whether baseline imbalance was addressed and other issues of analyzing continuous outcomes (e.g., how to handling missing data and skewed data).

Next, we selected six CERs to be used to evaluate the impact of using the change score or the followup score to estimate the MD. For this analysis, we only selected CERs conducted from 2005 onward, since most general systematic reviews were conducted earlier and CERs were more recent and relevant. To be included, the CER had to include at least one meta-analysis for continuous outcomes using mean difference. Only meta-analyses of RCTs were included in this study, and we specifically evaluated MD only. The CERs were selected to cover a wide range of commonly used continuous outcomes in health research (Table 1). We avoided including more than one CER that evaluated the same continuous outcome (duplicate outcome, e.g., if two CERs examined lipid variables or HbA1C, we only picked one of them). Also, we only considered the updated review if there was an earlier review and updated version (duplicate review). The medical conditions included hip fracture, obstructive sleep apnea, depression, diabetes, and alcohol abuse, and the interventions included pharmacologic, behavioral, and other therapies.

Table 1 Included comparative effectiveness reviews and continuous outcomes

Comparative Effectiveness Review Title | Publication Year | Continuous Outcomes | Number of Meta-Analyses
Pain Management Interventions for Hip Fracture15 | 2011 | Acute pain | 1
Diagnosis and Treatment of Obstructive Sleep Apnea in Adults16 | 2011 | Apnea-Hypopnea Index (AHI), Epworth Sleepiness Scale (ESS) | 6
Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults17 | 2011 | Depressive severity | 3
Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression: An Update of the 2007 Comparative Effectiveness Review18 | 2011 | Montgomery–Åsberg Depression Rating Scale (MADRS) | 1
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report19 | 2011 | Hemglobin A1C, Weight, LDL, HDL, Triglycerides | 50
Screening, Behavioral Counseling, and Referral in Primary Care To Reduce Alcohol Misuse20 | 2012 | Weekly alcohol use | 2

HDL = high-density lipoprotein; LDL = low-density lipoprotein.

A total of 63 meta-analyses were evaluated in this study; each meta-analysis needed to include at least 3 studies in order to be included. For each meta-analysis, we identified all original publications. One investigator abstracted data on outcomes, comparison groups, the analysis method and all data from the publication at baseline, followup, and any change data including estimates from analysis of covariance (ANCOVA) model, and a second investigator reviewed data abstraction for accuracy. We abstracted data based on the comparisons and time points included in each meta-analysis in the CER but did not use data from the CERs in our evaluation, as the data from the CERs were not adequate for the purpose of this study.

## Statistical Analysis

The characteristics of the systematic reviews were summarized descriptively. For each meta-analysis, we calculated two mean differences and the associated standard errors based on change score and followup score. When the standard deviation (SD) for baseline or followup score was missing, it was imputed using the mean SD from studies with reported SDs in that meta-analysis. The standard deviation of the change score, when not reported, was calculated from baseline and followup SDs by assuming that the correlation between baseline and followup was 0.5. When mean difference could not be calculated based on change score or followup score due to inadequately reported data, we used the ANCOVA estimate, or other estimate of mean difference available or reported in the publication (e.g., an estimate from a mixed effects model). When studies reported geometric mean and its standard deviation, we converted them to the mean and standard deviation on the raw scale.21

The mean difference estimates based on the change score or the followup score were separately combined using random effects models. We also assessed whether the baseline scores imbalance across the included studies was due to chance by meta-analyzing the baseline score differences between treatment groups.11 The patterns of baseline scores imbalance across the included studies could vary. However, if the baseline scores imbalance occurred by chance, the combined overall baseline score difference between treatment groups should be close to zero, in particular when the number of studies and the total number of patients randomized are large. This is a different issue from evaluating baseline scores imbalance within a single RCT.1,22,23

Given that different random effect models might affect the results of using different mean difference estimates, we evaluated alternative random effect estimators, and each meta-analysis was conducted using six random effects estimates: the Dersimonian-Laird (DL) method, the profile likelihood (PL) method, the maximum likelihood (ML) method, the restricted maximum likelihood (REML) method, the permutation (PE) method, and the Knapp-Hartung modification (KH) of random effect estimate.24 The primary analyses focused on results from the DL and PL methods as they are the methods with better performance.25,26

We assessed the presence of statistical heterogeneity among the studies by using the standard Cochran's chi-square test, and the magnitude of heterogeneity by using the I^2^ statistic.27 In addition, we conducted sensitivity analysis by using ANCOVA estimates whenever they were available (not only when the mean difference could not be calculated based on change score and followup score) and by assuming different values of correlation between baseline and followup. We did not use the ANCOVA estimates in the primary analyses as we aimed to focus on the comparison between using the change versus the followup score. For each random effect method, we qualitatively compared the combined estimates using the change score and followup score to see whether there was discrepancy in conclusion. Discrepancy in conclusion means one estimate shows statistically significant difference and the other estimate does not (i.e., the combined estimate using the mean difference based on the change score shows a statistically significant difference, while using the followup score does not; or vice versa). Further, qualitative difference means that two estimates show a difference in the magnitude of effect, but no discrepancy in conclusion.

All analyses were performed using Stata/IC 13.1 (StataCorp, College Station, TX).