# Introduction

In randomized controlled clinical trials (RCTs), continuous outcomes are typically measured at both baseline and followup time points, and mean difference is analyzed as the effect measure. There are multiple ways to estimate the mean difference: using the change score from the baseline, using the followup scores, or estimating the mean difference using the analysis of covariance (ANCOVA) model with the baseline score as a covariate. When using the ANCOVA analysis, either the followup score or the change score can be used as the dependent variable, and they are equivalent in estimating the mean difference. All of these estimates provide unbiased estimates of mean difference when the clinical trials are adequately randomized, and the ANCOVA estimate provides a more efficient estimator with more precision.1-3 Comparing using the change versus followup score, using the change score will provide a more precise estimate if the correlation between baseline and followup is high (> 0.5 if the standard deviations at baseline and followup are the same); otherwise, using the followup score will provide a more precise estimate.

The distribution of the baseline outcome scores is similar for adequately randomized RCTs. The distribution of the baseline outcome scores could become imbalanced in inadequately randomized trials, for example, due to chance, especially in small trials,4 or due to selection bias, often caused by inadequate randomization concealment.5 In addition, even for trials without baseline imbalance, systematic attrition linked to outcome is a concern, which may cause baseline imbalance (among patients with followup scores).6 Baseline imbalance occurs quite commonly in clinical trials. Hartling et al.7 reported that 35 percent of RCTs at high/unclear risk of bias in child health had imbalanced baseline distribution when this was subjectively evaluated as one of the methodological characteristics.

When the baseline scores are imbalanced, using either the change scores from the baseline or the followup scores would produce biased effect estimates of mean difference. Using the followup scores simply ignores baseline imbalance, and using the change score from the baseline, contrary to common belief, does not address the issue of the baseline imbalance. Instead, the change score is negatively associated with the baseline score, and patients with a worse baseline score are more likely to experience a high change score (regression to the mean). For instance, suppose that a trial has an intervention group and a placebo group, and the intervention group has a worse baseline score; then the treatment effect size from the intervention will be underestimated using the followup score and overestimated using the change score from baseline.8 When baseline imbalance occurs by chance, the ANCOVA method removes conditional bias in treatment group comparisons and improves efficiency over unadjusted comparisons.1-3 While the issue of baseline imbalance could be attenuated by using the ANCOVA model to adjust for baseline imbalance in individual studies, its impact on meta-analysis has not been well studied. In a meta-epidemiological study of osteoarthritis trials with pain scores as the clinical outcomes, Da Costa et al.9 found no evidence for systematic differences between standardized mean differences (SMD) derived from followup and change scores, and concluded that it is valid to combine followup and change scores. However, the study did not consider whether the baseline pain scores were balanced in the included studies. Other studies have emphasized the importance of considering the impact of baseline imbalance in meta-analyses10-12 and the use of ANCOVA estimates whenever possible.10,12 Nonetheless, for meta-analyses using study-level estimates, which is still the dominant approach to conducting meta-analyses, the choice of mean difference estimates has to depend on the reported data. Individual studies don't always report ANCOVA estimates, and they rarely report all the necessary data to calculate the ANCOVA estimates. Estimates using the change scores or followup scores for mean difference often become the practical choice.

Therefore, in this meta-epidemiological study, we empirically evaluated how the choice of using change scores or followup scores to estimate the mean difference impacted the meta-analyses, and whether the impact qualitatively varied by the comparator (whether the intervention was compared with a control group or multiple interventions were compared to each other), or linked with differences in baseline scores. For this paper, we specifically looked at mean difference for continuous outcomes measured in the same scale. In addition, we evaluated how different random effect models might affect the impact of the choice of mean difference estimates. A random effects model is generally recommended for combining continuous outcomes, and recently there has been a call to use alternative random-effects estimates to replace the universal use of Dersimonian-Laird random effects model.13