# Peer Reviewers

Prior to publication of the final report, the EPC sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Doug Altman
  Director, Centre for Statistics in Medicine and Cancer Research UK Medical Statistics Group
  University of Oxford
  Oxford, United Kingdom
- Joseph C. Cappelleri, Ph.D., M.P.H., M.S.
  Pfizer Inc
  Groton, CT
- Bruno R. da Costa, Bsc.P.T., M.Sc., Ph.D.
  Assistant Professor, Department of Physical Therapy
  Florida International University
  Miami, FL
- Steven H. Fox, M.D., S.M., M.P.H.
  Fulbright Senior Research Scholar
  National Taiwan University
  Taipei, Taiwan
- George Papandonatos, Ph.D.
  Associate Professor of Biostatistics
  Brown University
  Providence, RI