# Acknowledgments

The authors gratefully acknowledge Elaine Graham, M.L.S., and Amber L. Laurie, M.S., for their contributions to this project.