# Discussion

The issue of baseline imbalance was inadequately addressed in systematic reviews and comparative effectiveness reviews sponsored by AHRQ. To our knowledge, this is the first empirical evaluation of how using the change versus the followup score would affect the combined mean differences. Discrepancy in conclusions was shown in 5 out of the 63 meta-analysis (7.9%) using the DL method and 9 (14.3%) using the PL method. In general, the mean difference based on the change score was more likely to show significant results. While the conclusions were consistent in most cases, it was concerning to see that up to 14.3 percent of results were not. Such discrepancy emphasizes the need for careful selection of mean difference estimates, in particular, given the recent call for using alternative random-effects estimates, like the PL estimate, to replace the universal use of the DL random effects model.13 The common misconception was that using change scores accounts for baseline difference, and five of the six CERs used the change score to estimate the mean difference, even though using the change score does not address the baseline imbalance. These results support the current AHRQ guidance that advises review authors to conduct sensitivity analyses using both scores to assess the robustness of results to the choice of mean difference estimates.12

It was interesting that in the meta-analyses of intervention versus controls, the combined mean differences using the change score consistently showed larger treatment effect in all but one meta-analysis, and the relative difference could be as large as more than 40 percent higher. Since the change score was negatively associated with the baseline score, such results would occur when the baseline scores in the intervention groups were systematically worse. This was also roughly shown by the combined baseline differences and suggested potential bias in randomization that may not de due to chance (patients with a more severe condition were more likely to be randomized to the intervention group). Baseline imbalance due to systematic bias poses a more serious problem than baseline imbalance due to chance, which would not be as effectively adjusted for by using ANCOVA models. This finding warrants further study to evaluate its prevalence and impact in the literature.

Whenever there is baseline imbalance, using the change versus followup score to estimate mean difference would lead to some qualitative difference in the combined mean difference. Nevertheless, significant baseline difference does not necessarily lead to discrepancy in conclusions and discrepancy in conclusions does not necessarily occur when there is significant baseline difference. No other common characteristics relating to the size and number of included studies, type of outcomes, and between-study heterogeneity among discrepant meta-analyses were identified. When the correlation between baseline and followup is large, the standard error of the mean difference based on the change score will be smaller than the mean difference based on the followup score. This may play a role why the mean difference based on the change score was more likely to show significant results.

Both qualitative difference and discrepancy in conclusions are important. Sometimes, discrepancy in conclusion only reflects small shifts in numerical values. However, such shifts could be critical to consider and may have potential health policy implications since it is unavoidable to use the cutoff points of P-values in the current scientific world and some health decisions could be affected by such shifts. While this study is not powered to look at the association between significant baseline difference and discrepancy in conclusions, in theory, discrepancy in conclusions should be a function of the magnitude of baseline difference, magnitude of effect, and heterogeneity between (and within) studies. When the significance of effect is closer to borderline, significant baseline difference may be more likely to lead to discrepancy in conclusions. Whether or not significant baseline difference is directly linked with discrepancy in conclusions, it highlights the importance to evaluate specifically baseline imbalance for each meta-analysis.

Results on discrepancy in conclusions based on the ML method are similar to the DL method and those based on the REML method are similar to the PL method. Further, an additional purpose of comparing these methods was to provide some empirical examples and practical sense of how much the estimates differed among the methods. The results were consistent with simulation studies in that the DL and PL methods generally provided wider CIs and better coverage probability than ML and REML methods, though the PL method did not converge in a small proportion of meta-analyses, and the 95 percent CIs based on the PE method are too wide and conservative for general use.25,26 Interestingly, the KH modification produced the most discrepancy, and it generally produced a wider CI than the DL and PL methods. Though the KH modification has been shown to result in more adequate error rates than the DL method,28 its overall performance has been shown not to be better than the DL and PL methods.25

We did not use the Trowman's method11 or the modified Trowman's method10 to adjust summary baseline score using meta-regression because it has been shown that such methods could provide misleading results.10 There is general agreement within the literature that estimates from the ANCOVA model are least biased to estimate mean difference in the presence of baseline imbalance due to chance. When the variance of the baseline score equals the variance of the followup score, the ANCOVA estimate is the weighted sum of the two estimates from change score and followup score, and the weight is the correlation between baseline and followup score.29 However, meta-regression adjusts the summary baseline score only in the study level. It is an ANCOVA-analogue analysis using study level data and ecological fallacy could play a role here. Results from Riley et al.10 showed that the adjustment using ANCOVA model and individual patient-level data (IPD) could not be achieved by using summary baseline score in meta-regression, but were limited to a couple of examples. More research is needed to determine whether adjusting the summary baseline score in a meta-regression is useful at all.

In the presence of baseline imbalance, the ANCOVA estimates should be used in a meta-analysis whenever reported.10,12 Unfortunately, in this study, we found that the reporting of ANCOVA estimates has been poor, even though many trials used an ANCOVA model in their analyses. The importance of adequate reporting of such estimates needs to be better recognized among the authors and journal editors. The actual ANCOVA estimates should be reported when such analyses were conducted so they could be properly used in evidence synthesis and potential health policy decision making. On the other hand, this is one situation where availability of IPD would provide the best solution, where baseline imbalance could be consistently adjusted using ANCOVA model across studies. IPD could also address the concern that systematic attrition may lead to baseline imbalance (among patients with followup scores),6 and provide the means to better handle missing data in general.

We tried to evaluate a wide range of outcomes in this analysis, but choice of outcomes was limited by the outcomes studied in CERs published by AHRQ during the study period. Most outcomes were related to diabetes and came from one review19 with multiple studies included in more than one meta-analysis. This would affect the generalizability the results. However, these meta-analyses did address multiple key questions, outcomes, interventions and comparators, and it was valuable to study the choice of estimates for mean difference in such a complex CER. Many other commonly used continuous outcomes such as pain, quality of life, and functional status were not assessed or not adequately assessed. They will be evaluated in future research.

We specifically focused only on MD in this study without looking at SMD. Baseline imbalance directly affects the MD, but the choice of change score versus followup score has further implications on estimating SMD. The standard deviation is also involved in calculating SMD and the standard deviations are calculated differently when using change score versus followup score. Da Costa et al.9 found no evidence for systematic differences between SMDs derived from followup and change pain scores without evaluating the impact of baseline scores, but as MD, the overall evidence is still limited.

Only RCTs were included in this study and RCT is the most commonly used study design of the included studies in CERs to evaluate effectiveness. Other designs, like cohort or other observational studies were not considered. The issue of baseline imbalance in observational studies was different from RCTs since baseline balance was not expected and Lord's paradox could further complicate the analysis.30

In summary, using the change score versus the followup score to estimate MD could lead to important discrepancy in conclusions. Using the change score is more likely to produce significant results when there are discrepancies in conclusions based on this study, though the overall evidence is limited; and using the followup score is more likely produce more conservative results. Sensitivity analyses using both change scores and final values should be conducted to check the robustness of results to the choice of mean difference estimates.