# Comparison of Combined Mean Differences Using Change Score and Endpoints (Comparison Between Different Treatments)

Comparative Effectiveness Review | Outcome Comparison (Group #1 vs. Group #2) | Number of Studies (N) Group #1 and Group #2 Total Sample Size (Min-Max) | Baseline Difference (95% CI) | Difference in Change Score (95% CI) | Difference in Endpoint Score (95% CI)
Diagnosis and Treatment of Obstructive Sleep Apnea in Adults 16 | Apnea-Hypopnea Index: AutoCPAP vs. CPAP | 6 studies #1: 115 (10–50) #2: 116 (10–50) | PL: 1.004 (-3.766, 5.783) DL: 1.004 (-3.767, 5.775) REML: 1.004 (-3.767, 5.775) ML: 1.004 (-3.767, 5.775) PE: 1.004 (-8.0e+15, 2.058) KH: 1.004 (-5.253, 7.262) I^2^ = 0%, P = 0.938 | PL: -0.844 (-5.359, 3.646) DL: -0.844 (-5.330, 3.643) REML: -0.844 (-5.330, 3.643) ML: -0.844 (-5.330, 3.643) PE: -0.844 (-35.933, 1.3e+16) KH: -0.844 (-6.728, 5.040) 0.0%, P = 0.975 | PL: -0.326 (-2.710, 2.058) DL: -0.448 (-2.519, 1.928) REML: -0.402 (-2.461, 1.658) ML: -0.448 (-2.351, 1.455) PE: -0.326 (-1.7e+16, 1.058) KH: -0.402 (-3.102, 2.299) I^2^ = 80.8%, P < 0.001
Diagnosis and Treatment of Obstructive Sleep Apnea in Adults 16 | Epworth Sleepiness Scale: AutoCPAP vs. CPAP | 5 studies #1: 112 (10–50) #2: 103 10–50) | PL: -0.880 (-2.840, 0.568) DL: -0.959 (-2.467, 0.548) REML: -0.977 (-2.518, 0.564) ML: -0.880 (-2.261, 0.501) PE: Not calculable^a^ KH: 1.004 (-5.253, 7.262) I^2^ = 26.3%, P = 0.246 | PL: 0.959 (-0.313, 2.628) DL: 0.959 (-0.299, 2.216) REML: 0.995 (-0.316, 2.306) ML: 0.959 (-0.299, 2.216) PE: Not calculable^a^ KH: 0.995 (-0.862, 2.852) I2 = 0%, P = 0.452 | PL: -0.085 (-1.176, 1.028) DL: -0.085 (-1.155, 0.984) REML: -0.085 (-1.155, 0.984) ML: -0.085 (-1.155, 0.984) PE: Not calculable^a^ KH: -0.085 (-1.600, 1.429) I^2^ = 0%, P = 0.785
Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression: An Update of the 2007 Comparative Effectiveness Review 18 | MADRS: citalopram vs. escitalopram | 6 studies #1: 939 (125–214) #2: 932 (108–241) | PL: 0.178 (-0.341, 0.646) DL: 0.171 (-0.283, 0.625) REML: 0.171 (-0.285, 0.626) ML: 0.178 (-0.245, 0.601) PE: 0.171, -0.798, 0.443) KH: 0.171 (-0.426, 0.768) I^2^ = 12.7%, P = 0.333 | PL: 2.108 (0.078, 4.008)^b^ DL: 2.077 (0.174, 3.979) REML: 2.086 (0.258, 3.914) ML: 2.108 (0.418, 3.798) PE: 2.077 (0.000, 6.109) KH: 2.042 (-0.316, 4.400) I^2^ = 67.8%, P = 0.008 | PL: 2.258 (-0.073, 4.430)^b^ DL: 2.221 (0.060, 4.383) REML: 2.231 (0.139, 4.323) ML: 2.258 (0.330, 4.186) PE: 2.221 (-0.000, 6.552) KH: 2.231 (-0.513, 4.975) I^2^ = 68.7%, P = 0.007
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HbA1c: metformin vs. thiazolidinediones | 14 studies #1: 1132 (13–501) #2: 1127 (14–499) | PL: -0.017 (-0.097, 0.062) DL: -0.017 (-0.109, 0.074) REML: -0.017 (-0.094, 0.060) ML: -0.017 (-0.094, 0.060) PE: -0.017 (-0.226, 0.034) KH: -0.017 (-0.107, 0.072) I^2^ = 9.7%, P = 0.347 | PL: -0.105 (-0.188, -0.025)^b^ DL: -0.106 (-0.214, 0.003) REML: -0.105 (-0.183, -0.027)^c^ ML: -0.105 (-0.183, -0.027)^c^ PE: -0.106 (-0.550, 0.005) KH: -0.105 (-0.204, -0.005)^c^ I^2^ = 24.9%, P = 0.186 | PL: -0.054 (-0.186, 0.103)^b^ DL: -0.053 (-0.182, 0.077) REML: -0.050 (-0.186, 0.087)^c^ ML: -0.054 (-0.181, 0.074)^c^ PE: -0.053 (-0.452, 0.058) KH: -0.050 (-0.220, 0.121)^c^ I^2^ = 58.0%, P = 0.003
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HbA1c: metformin vs. sulfonylureas | 17 studies #1: 1153 (16–210) #2: 1229 (17–209) | PL: 0.042 (-0.087, 0.169) DL: 0.044 (-0.066, 0.153) REML: 0.042 (-0.082, 0.166) ML: 0.042 (-0.078, 0.162) PE: 0.044 (-0.208, 0.119) KH: 0.042 (-0.093, 0.176) I^2^ = 14.7%, P = 0.282 | PL: 0.060 (-0.113., 0.228) DL: 0.058 (-0.115, 0.232) REML: 0.059 (-0.107, 0.225)^c^ ML: 0.060 (-0.101, 0.220)^c^ PE: 0.058 (-0.237, 0.159) KH: 0.059 (-0.12, 0.238) I^2^ = 62.4%, P < 0.001 | PL: 0.116 (-0.005, 0.233) DL: 0.115 (-0.008, 0.237) REML: 0.115 (0.001, 0.230)^c^ ML: 0.116 (0.005, 0.226)^c^ PE: 0.115 (-0.027, 0.180) KH: 0.115 (-0.018, 0.249) I^2^ = 51.8%, P = 0.007
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HbA1c: metformin vs. DPP-4 inhibitors | 3 studies #1: 1037 (243–439) #2: 855 (175–455) | PL: -0.039 (-0.210, 0.047) DL: -0.066 (-0.178, 0.047) REML: -0.066 (-0.180, 0.048) ML: -0.039 (-0.110, 0.032) PE: Not calculable^a^ KH: -0.066 (-0.316, 0.183) I^2^ = 43.9%, P = 0.168 | PL: -0.184 (-0.387, -0.049) DL: -0.203 (-0.354, -0.052) REML: -0.201 (-0.348, -0.055) ML: -0.184 (-0.299, -0.069) PE: Not calculable^a^ KH: -0.201 (-0.523, 0.12) I^2^ = 62.7%, P = 0.068 | PL: -0.301 (-0.606, -0.028) DL: -0.312 (-0.593, -0.030) REML: -0.308 (-0.558, -0.058) ML: -0.301 (-0.509, -0.093) PE: Not calculable^a^ KH: -0.308 (-0.857, 0.241) I^2^ = 87.7%, P < 0.001
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HbA1c: metformin vs. metformin and thiazolidinediones | 11 studies #1: 1428 (34–277) #2: 1688 (60–296) | PL: -0.160 (-0.283, -0.034)^b^ DL: -0.158 (-0.290, -0.027)^b^ REML: -0.160 (-0.280, -0.039)^c^ ML: -0.160 (-0.276, -0.044)^c^ PE: -0.158 (-0.624, -0.013) KH: -0.160 (-0.296, -0.023) I^2^ = 69.6%, P = 0.001 | PL: 0.633 (0.432, 0.854) DL: 0.635 (0.437, 0.832) REML: 0.636 (0.435, 0.837) ML: 0.633 (0.442, 0.824) PE: 0.635 (0.399, 0.866) KH: 0.636 (0.406, 0.866) I^2^ = 85.5%, P < 0.001 | PL: 0.503 (0.280, 0.733) DL: 0.506 (0.268, 0.744) REML: 0.504 (0.287, 0.721) ML: 0.503 (0.295, 0.710) PE: 0.506 (0.313, 0.659) KH: 0.504 (0.257, 0.751) I^2^ = 93.4%, P < 0.001
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HbA1c: metformin vs. metformin and sulfonylureas | 14 studies #1: 1188 (16–210) #2: 1949 (23–323) | PL: 0.043 (-0.085, 0.147) DL: 0.033 (-0.090, 0.156) REML: 0.039 (-0.068, 0.146) ML: 0.043 (-0.054, 0.140) PE: 0.033 (-0.155, 0.110) KH: 0.039 (-0.101, 0.179) I^2^ = 42.3%, P = 0.048 | PL: 0.848 (0.627, 1.098) DL: 0.851 (0.629, 1.073) REML: 0.852 (0.627, 1.077) ML: 0.848 (0.632, 1.063) PE: 0.851 (0.571, 1.115) KH: 0.852 (0.598, 1.106) I^2^ = 80.7%, P < 0.001 | PL: 0.832 (0.564, 1.117) DL: 0.837 (0.558, 1.116) REML: 0.834 (0.568, 1.100) ML: 0.832 (0.576, 1.087) PE: 0.837 (0.511, 1.136) KH: 0.834 (0.535, 1.134) I^2^ = 92.6%, P < 0.001
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HbA1c: metformin vs. metformin and DPP-4 Inhibitors | 6 studies #1: 1177 (88–355) #2: 2075 (91–552) | PL: -0.001 (-0.083, 0.067) DL: -0.001 (-0.069, 0.067) REML: -0.001 (-0.069, 0.067) ML: -0.001 (-0.069, 0.067) PE: -0.001 (-5.1e+14, 0.033) KH: -0.001 (-0.090, 0.088) I^2^ = 0%, P = 0.478 | PL: 0.596 (0.469, 0.764) DL: 0.603 (0.475, 0.731) REML: 0.605 (0.473, 0.736) ML: 0.596 (0.488, 0.704) PE: 0.603 (-1.000, 0.912) KH: 0.601 (0.420, 0.782) I^2^ = 51.8%, P = 0.065 | PL: 0.592 (0.479, 0.712) DL: 0.593 (0.485, 0.701) REML: 0.593 (0.485, 0.700) ML: 0.592 (0.494, 0.689) PE: 0.593 (0.426, 0.775) KH: 0.593 (0.452, 0.734) I^2^ = 41.2%, P = 0.131
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HbA1c: thiazolidinediones vs. sulfonylureas | 13 studies #1: 1202 (15–384) #2: 1013 (15–251) | PL: -0.017 (-0.150, 0.084) DL: -0.025 (-0.141, 0.092) REML: -0.020 (-0.124, 0.083) ML: -0.017 (-0.108, 0.074) PE: -0.025 (-0.295, 0.050) KH: -0.020 (-0.147, 0.106) I^2^ = 26.5%, P = 0.176 | PL: 0.029 (-0.143, 0.207) DL: 0.029 (-0.128, 0.185) REML: 0.031 (-0.136, 0.198) ML: 0.029 (-0.128, 0.186) PE: 0.029 (-0.284, 0.131) KH: 0.031 (-0.155, 0.216) I^2^ = 35.7%, P = 0.097 | PL: -0.077 (-0.262, 0.103) DL: -0.078 (-0.257, 0.101) REML: -0.077 (-0.253, 0.098) ML: -0.077 (-0.244, 0.091) PE: -0.078 (-0.504, 0.064) KH: -0.077 (-0.272, 0.117) I^2^ = 71.9%, P < 0.001
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HbA1c: sulfonylureas vs. meglitinides | 7 studies #1: 563 (15–171) #2: 924 (29–338) | PL: 0.034 (-0.136, 0.193) DL: 0.033 (-0.107, 0.173) REML: 0.032 (-0.120, 0.184) ML: 0.034 (-0.104, 0.171) PE: 0.033 (-0.846, 0.099) KH: 0.032 (-0.158, 0.222) I^2^ = 8.0%, P = 0.367 | PL: 0.072 (-0.146, 0.322) DL: 0.074 (-0.123, 0.271) REML: 0.078 (-0.137, 0.293) ML: 0.072 (-0.119, 0.263) PE: 0.074 (-2.076, 0.254) KH: 0.078 (-0.19, 0.347) I^2^ = 44.7%, P = 0.093 | PL: 0.109 (-0.111, 0.359) DL: 0.113 (-0.096, 0.321) REML: 0.114 (-0.101, 0.330) ML: 0.109 (-0.082, 0.300) PE: 0.113 (-0.204, 0.229) KH: 0.114 (-0.159, 0.388) I^2^ = 54.2%, P = 0.042
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Hba1c: metformin and thiazolidinediones vs. metformin and sulfonylureas | 6 studies #1: 1055 (48–285) #2: 1039 (47–288) | PL: 0.038 (-0.059, 0.118) DL: 0.037 (-0.040, 0.114) REML: 0.035 (-0.045, 0.116) ML: 0.038 (-0.036, 0.113) PE: 0.037 (-0.218, 0.077) KH: 0.035 (-0.070, 0.141) I^2^ = 3.3%, P = 0.395 | PL: 0.090 (-0.091, 0.268) DL: -0.090 (-0.061, 0.241) REML: 0.090 (-0.075, 0.254) ML: 0.090 (-0.056, 0.236) PE: 0.090 (-0.168, 0.208) KH: 0.09 (-0.138, 0.317) I^2^ = 68.5%, P = 0.007 | PL: 0.136 (-0.049, 0.308) DL: 0.135 (-0.021, 0.291) REML: 0.134 (-0.031, 0.298) ML: 0.136 (-0.012, 0.284) PE: 0.135 (-0.236, 0.260) KH: 0.134 (-0.088, 0.356) I^2^ = 71.5%, P = 0.004
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Hba1c: metformin and Sulfonylureas vs. Thiazolidinediones and Sulfonylureas | 6 studies #1: 847 (37–320) #2: 871 (34–319) | PL: -0.123 (-0.238, 0.008) DL: -0.126 (-0.217, -0.034)^b^ REML: -0.119 (-0.231, -0.006)^c^ ML: -0.123 (-0.221, -0.025)^c^ PE: -0.126 (-3.493, 1.1e+15) KH: -0.119 (-0.266, 0.029) I^2^ = 8.3%, P = 0.363 | PL: -0.050 (-0.151, 0.069)^b^ DL: -0.050 (-0.148, 0.047)^b^ REML: -0.050 (-0.148, 0.047)^c^ ML: -0.050 (-0.148, 0.047)^c^ PE: -0.050 (-1.296, 0.016) KH: -0.05 (-0.178, 0.078)^c^ I^2^ = 0%, P = 0.628 | PL: -0.165 (-0.262, -0.061)^b^ DL: -0.165 (-0.262, -0.068)^b^ REML: -0.165 ( -0.262, -0.068)^c^ ML: -0.165 (-0.262, -0.068)^c^ PE: -0.165 (-3.106, 0.008) KH: -0.165 (-0.292, -0.038)^c^ I^2^ = 30.7%, P = 0.205
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: metformin vs. thiazolidinediones | 8 studies #1: 802 (13–501) #2: 816 (14–499) | PL: 1.328 (-0.697, 2.836) DL: 1.328 (-0.125, 2.781) REML: 1.328 (-0125, 2.781) ML: 1.328 (-0.125, 2.781) PE: 1.328 (-6.058, 2.089) KH: 1.328 (-0.320, 2.976)^e^ I^2^ = 0%, P = 0.550 | PL: -2.877 (-4.229, -1.488) DL: -2.873 (-4.118, -1.629) REML: -2.870 (-4.161, -1.579) ML: -2.877 (-4.079, -1.675) PE: -2.873 (-19.057, -0.271) KH: -2.87 (-4.433, -1.307) I^2^ = 83.0%, P < 0.001 | PL: -3.184 (-4.446, -1.025) DL: -3.104 (-4.428, -1.780) REML: -2.968 ( -4.486, -1.450) ML: -3.184 (-4.405, -1.963) PE: -3.104 (-39.375, -0.038) KH: -2.968 (-4.800, -1.137) I^2^ = 21.6%, P = 0.258
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: metformin vs. sulfonylureas | 12 studies #1: 987 (16–210) #2: 1066 (17–209) | PL: 0.623 (-0.895, 1.889) DL: 0.515 (-1.005, 2.034) REML: 0.623 (-0.638, 1.883) ML: 0.623 (-0.638, 1.883) PE: 0.515 (-1.427, 1.439) KH: 0.623 (-1.006, 2.252) I^2^ = 24.5%, P = 0.203 | PL: -2.635 (-3.157, -2.127) DL: -2.637 (-3.155, -2.120) REML: -2.636 (-3.132, -2.140) ML: -2.635 (-3.112, -2.158) PE: -2.637 (-8.701, -0.653) KH: -2.636 (-3.192, -2.079) I^2^ = 52.7%, P = 0.016 | PL: -1.757 (-3.282, -0.423) DL: -1.847 (-3.434, -0.260) REML: -1.759 (-3.049, -0.468) ML: -1.757 (-3.033, -0.482) PE: -1.847 (-7.651, -0.161) KH: -1.759 (-3.454, -0.063) I^2^ = 27.8%, P = 0.172
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: metformin vs. sulfonylureas (studies < 24 weeks in duration) | 8 studies #1: 718 (21–164) #2: 797 (18–161) | PL: 1.669 (0.115, 3.208)^b^ DL: 1.669 (0.163, 3.175)^b^ REML: 1.669 (0.163, 3.175)^c^ ML: 1.669 (0.163, 3.175)^c^ PE: 1.669 (0.890, 2.533) KH: 1.669 (-0.148, 3.486) I^2^ = 0%, P = 0.939 | PL: -2.240 (-2.747, -1.792)^b^ DL: -2.234 (-2.640, -1.828)^b^ REML: -2.250 (-2.700, -1.801)^c^ ML: -2.240 (-2.659, -1.821)^c^ PE: -2.234 (-14.999, -0.310) KH: -2.250 (-2.793, -1.708)^c^ I^2^ = 2.8%, P = 0.408 | PL: -0.634 (-2.144, 0.852)^b^ DL: -0.634 (-2.118, 0.850)^b^ REML: -0.634 (-2.118, 0.850)^c^ ML: -0.634 (-2.118, 0.850)^c^ PE: -0.634 (-6.145, 0.211) KH: -0.634 (-2.424, 1.157)^c^ I^2^ = 0%, P = 0.883
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: metformin vs. sulfonylureas (studies ≥ 24 weeks in duration) | 4 studies #1: 269 (16–210) #2: 269 (17–209) | PL: -2.979 (-8.174, 0.976) DL: -3.259 (-7.386, 0.867) REML-3.256 (-7.375, 0.863) ML: -2.979 (-6.542, 0.583) PE: Not calculable^a^ KH: -3.256 (-9.945, 3.432) I^2^ = 50.5%, P = 0.109 | PL: -3.531 (-4.232, -2.940) DL: -3.531 (-4.041, -3.022) REML: -3.531 (-4.041, -3.022) ML: -3.531 (-4.041, -3.022) PE: Not calculable^a^ KH: -3.531 (-4.359, -2.704)^c^ I^2^ = 0%, P = 0.904 | PL: -4.940 (-11.360, -2.359) DL: -5.837 (-9.383, -2.290) REML: -6.213 (-10.240, -2.186) ML: -4.940 (-7.521, -2.359) PE: Not calculable^a^ KH: -6.213 (-12.751, 0.325)^c^ I^2^ = 21.4%, P = 0.282
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: metformin vs. DPP-4 Inhibitors | 3 studies #1: 937 (243–446) #2: 783 (100–458) | PL: -0.300 (-2.920, 2.320) DL: -0.300 (-2.920, 2.320) REML: Not calculable ML: -0.300 (-2.920, 2.320) PE: Not calculable^a^ KH: -0.300 (-0.496, -0.104)^e^ I^2^ = Not applicable^d^ P = Not applicable^d^ | PL: -1.280 (-1.793, -0.677) DL: -1.251 (-1.830, -0.672) REML: -1.254 (-1.796, -0.712) ML: -1.280 (-1.594, -0.966) PE: Not calculable^a^ KH: -1.254 (-2.628, 0.120)^c^ I^2^ = 47.8%, P = 0.147 | PL: -1.360 (-1.959, -0.944) DL: -1.360 (-1.689, -1.032) REML: -1.360 (-1.689, -1.032) ML: -1.360 (-1.689, -1.032) PE: Not calculable^a^ KH: -1.360 (-2.082, -0.639)^c^ I^2^ = 0%, P = 0.522
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: metformin vs. combination metformin and thiazolidinediones | 5 studies #1: 665 (86–280) #2: 786 (83–288) | PL: -1.194 (-3.881, 1.884) DL: -1.194 (-3.420, 1.031) REML: -1.194 (-3.420, 1.031) ML: -1.194 (-3.420, 1.031) PE: Not calculable^a^ KH: -1.194 (-15.621, 13.232) I^2^ = 0%, P = 0.706 | PL: -2.359 (-2.768, -1.982) DL: -2.359 (-2.737, -1.981) REML: -2.359 (-2.737, -1.981) ML: -2.359 (-2.737, -1.981) PE: Not calculable^a^ KH: -2.359 (-2.895, -1.824) I^2^ = 0%, P = 0.893 | PL: -2.686 (-3.500, -1.993) DL: -2.686 (-3.361, -2.012) REML: -2.686 (-3.361, -2.012) ML: -2.686 (-3.361, -2.012) PE: Not calculable^a^ KH: -2.686 (-3.642, -1.731) I^2^ = 0%, P = 0.931
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: metformin vs. combination metformin and sulfonylureas | 10 studies #1: 992 (16–210) #2: 1535 (23–323) | PL: 0.428 (-0.935, 1.903) DL: 0.428 (-0.933, 1.789) REML: 0.428 (-0.933, 1.789) ML: 0.428 (-0.933, 1.789) PE: 0.428 (-0.965, 0.709) KH: 0.428 (-1.174, 2.029) I^2^ = 0%, P = 0.960 | PL: -2.197 (-2.896, -1.440) DL: -2.168 (-2.960, -1.375) REML: -2.189 (-2.884, -1.493) ML: -2.197 (-2.861, -1.533) PE: -2.168 (-9.086, -0.468) KH: -2.189 (-2.991, -1.386) I^2^ = 84.4%, P < 0.001 | PL: -2.394 (-3.057, -1.481) DL: -2.394 (-3.020, -1.768) REML: -2.394, -3.020, -1.768) ML: -2.394 (-3.020, -1.768) PE: -2.394 (-27.001, -0.197) KH: -2.394 (-3.117, -1.671) I^2^ = 0%, P = 0.868
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: metformin vs. combination metformin and sulfonylureas | 3 studies #1: 579 (88–248) #2: 910 (91–523) | PL: 0.683 (-1.821, 3.545) DL: 0.683 (-1.384, 2.751) REML: 0.683 (-1.384, 2.751) ML: 0.683 (-1.384, 2.751) PE: Not calculable^a^ KH: 0.683 (-12.719, 14.086) I^2^ = 0%, P = 0.714 | PL: -0.200 (-0.601, 0.247) DL: -0.200 (-0.584, 0.184) REML: -0.200 (-0.584, 0.184) ML: -0.200 (-0.584, 0.184) PE: Not calculable^a^ KH: -0.200 (-1.043, 0.642) I^2^ = 0%, P = 0.639 | PL: 0.004 (-0.810, 1.124) DL: 0.004 (-0.644, 0.652) REML: 0.004 (-0.644, 0.652) ML: 0.004 (-0.644, 0.652) PE: Not calculable^a^ KH: 0.004 (-0.595, 0.603)^e^ I^2^ = 0%, P = 0.838
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: thiazolidinediones vs. sulfonylureas | 5 studies #1: 883 (23–384) #2: 694 (18–251) | PL: 0.298 (-1.479, 2.327) DL: 0.298 (-1.479, 2.076) REML: 0.298 (-1.479, 2.076) ML: 0.298 (-1.479, 2.076) PE: Not calculable^a^ KH: 0.298 (-2.588, 3.184) I^2^ = 0%, P = 0.676 | PL: 0.407 (-1.509, 2.210) DL: 0.402 (-1.136, 1.940) REML: 0.385 (-1.310, 2.079) ML: 0.407 (-1.094, 1.909) PE: Not calculable^a^ KH: 0.385 (-2.015, 2.785)^c^ I^2^ = 80.7%, P < 0.001 | PL: 1.114 (-0.378, 2.592) DL: 1.114 (-0.363, 2.590) REML: 1.114 (-0.363, 2.590) ML: 1.114 (-0.363, 2.590) PE: Not calculable^a^ KH: 1.114 (0.001, 2.226)^c,e^ I^2^ = 0%, P = 0.889
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: sulfonylureas vs. meglitinides | 6 studies #1: 518 (15–182) #2: 808 (29–362) | PL: 0.428 (-1.172, 2.318) DL: 0.507 (-1.509, 2.522) REML: 0.428 (-0.902, 1.758) ML: 0.428 (-0.902, 1.758) PE: Not calculable^a^ KH: 0.428 (-2.109, 2.966) I^2^ = 44.9%, P = 0.123 | PL: -0.176 (-0.894, 0.649) DL: -0.157 (-0.853, 0.538) REML: -0.156 (-0.859, 0.547) ML: -0.176 (-0.791, 0.439) PE: -0.157 (-15.284, 0.270) KH: -0.156 (-1.078, 0.767) I^2^ = 47.3%, P = 0.091 | PL: 0.192 (-0.990, 1.585) DL: 0.254 (-1.150, 1.659) REML: 0.192 (-0.963, 1.346) ML: 0.192 (-0.963,1.346) PE: 0.254 (-4.8e+15, 1.371) KH: 0.192 (-1.550, 1.933) I^2^ = 24.4%, P = 0.251
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: combination metformin and thiazolidinediones vs. combination metformin and sulfonylureas | 5 studies #1: 845 (48–294) #2: 864 (47–301) | PL: 0.396 (-1.871, 2.863) DL: 0.457 (-1.748, 2.661) REML: 0.446 (-1.672, 2.565) ML: 0.396 (-1.454, 2.247) PE: Not calculable^a^ KH: 0.446 (-2.994, 3.887) I^2^ = 65.3%, P = 0.034 | PL: 0.261 (-0.785, 1.339) DL: 0.273 (-0.860, 1.407) REML: 0.267 (-0.706, 1.239) ML: 0.261 (-0.619, 1.141) PE: Not calculable^a^ KH: 0.267 (-1.111, 1.644) I^2^ = 90.3%, P < 0.001 | PL: 0.546 (-2.003, 3.253) DL: 0.568 (-1.757, 2.894) REML: 0.576 (-1.821, 2.973) ML: 0.546 (-1.601, 2.692) PE: Not calculable^a^ KH: 0.576 (-2.820, 3.972) I^2^ = 88.3%, P < 0.001
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Weight: metformin and sulfonylureas vs. combination thiazolidinediones and sulfonylureas. | 4 studies #1: 653 (37–320) #2: 646 (34–319) | PL: 1.746 (-2.856, 6.117) DL: 1.672 (-2.815, 6.160) REML: 1.702 (-2.320, 5.724) ML: 1.746 (-1.792, 5.284) PE: Not calculable a KH: 1.702 (-4.828, 8.233) I^2^ = 87.5%, P < 0.001 | PL: -2.689 (-3.840, -1.550)^b^ DL: -2.689 (-3.747, -1.631)^b^ REML: -2.688 (-3.712, -1.665)^c^ ML: -2.689 (-3.574, -1.804)^c^ PE: Not calculable^a^ KH: -2.688 (-4.350, -1.027)^c^ I^2^ = 78.1%, P = 0.003 | PL: -0.935 (-6.105, 3.972)^b^ DL: -1.038 (-6.510, 4.434)^b^ REML: -0.981 (-5.511, 3.549)^c^ ML: -0.935 (-4.944, 3.075)^c^ PE: Not calculable^a^ KH: -0.981 (-8.336, 6.374)^c^ I^2^ = 90.8%, P < 0.001
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | LDL: metformin vs. rosiglitazone | 6 studies #1: 198 ( 9–117) #2: 213 (14–128) | PL: 2.100 (-4.188, 8.886) DL: 2.100 (-3.960, 8.159) REML: 2.100 (-3.960, 8.159) ML: 2.100 (-3.960, 8.159) PE: 2.100 (-13.062, 8.122) KH: 2.100 (-5.848, 10.047) I^2^ = 0.0%, P = 0.682 | PL: -12.535 (-22.237, -5.876)^b^ DL: -13.263 (-20.553, -5.974) REML: -13.249 (-20.495, -6.003)^c^ ML: -12.535 (-17.993, -7.077) PE: -13.263 (-133.809, -0.000) KH: -13.249 (-23.870, -2.628)^c^ I^2^ = 58.0%, P = 0.036 | PL: -14.009 (-29.491, 2.268)^b^ DL: -13.944 (-27.561, -0.327) REML: -13.858 (-28.448, 0.733)^c^ ML: -14.009 (-26.990, -1.028) PE: -13.944 (-126.845, 2.438) KH: -13.858 (-33.699, 5.984)^c^ I^2^ = 65.7%, P = 0.012
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | LDL: metformin vs. pioglitazone | 6 studies #1: 676 (16–501) #2: 679 (14–499) | PL: 4.325 (-5.729, 14.373) DL: 4.325 (-5.644, 14.294) REML: 4.325 (-5.644, 14.294) ML: 4.325 (-5.644, 14.294) PE: Not calculable^a^ KH: 4.325 (-11.861, 20.512) I^2^ = 0.0%, P = 0.935 | PL: -12.394 (-17.705, -6.587) DL: -12.394 (-17.684, -7.105) REML: -12.394 (-17.684, -7.105) ML: -12.394 (-17.684, -7.105) PE: -12.394 (-354.099, -0.000) KH: -12.394 (-19.332, -5.457) I^2^ = 0%, P = 0.848 | PL: -11.513 (-17.022, -2.810) DL: -11.141 (-17.152, -5.130) REML: -11.304 (-17.056, -5.552) ML: -11.513 (-16.946, -6.080) PE: -11.141 (-367.467, 0.797) KH: -11.304 (-19.063, -3.545) I^2^ = 10.6%, P = 0.348
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | LDL: metformin vs. sulfonylureas | 8 studies #1: 679 (16–210) #2: 671 (17–209) | PL: 1.146 (-4.930, 6.028) DL: 1.096 (-3.724, 5.916) REML: 0.950 (-4.130, 6.029) ML: 1.146 (-3.594, 5.886) PE: 1.096 (-52.943, 4.163) KH: 0.950 (-5.392, 7.291) I^2^ = 32.0%, P = 0.184 | PL: Does not converge DL: -7.717 (-13.175, -2.260) REML: -7.130 (-11.644, -2.616) ML: Does not converge PE: -7.717 (-51.181, -0.977) KH: -7.130 (-12.576, -1.684) I^2^ = 75.6%, P < 0.001 | PL: -7.229 (-13.707, -2.382) DL: -7.743 (-13.328, -2.158) REML: -7.494 (-12.651, -2.338) ML: -7.229 (-11.991, -2.467) PE: -7.743 (-49.429, -0.748) KH: -7.494 (-13.715, -1.274) I^2^ = 80.6%, P < 0.001
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | LDL: metformin vs. DPP-4 Inhibitors | 3 studies #1: 910 (239–426) #2: 791 (94–441) | PL: -1.733 (-9.626, 5.760) DL: -1.828 (-8.387, 4.730) REML: -1.831 (-8.447, 4.784) ML: -1.733 (-7.0874, 3.618) PE: Not calculable^a^ KH: -1.831 (-16.414, 12.751) I^2^ = 75.5%, P = 0.017 | PL: -6.281 (-10.313, -0.622) DL: -6.094 (-10.015, -2.172) REML: -5.993 (-10.141, -1.845) ML: -6.281 (-9.848, -2.714) PE: Not calculable^a^ KH: -5.993 (-15.099, 3.114) I^2^ = 13.9%, P = 0.313 | PL: -6.390 (-11.167, -2.276) DL: -6.444 (-10.253, -2.635) REML: -6.390 (-9.815, -2.966) ML: -6.390 (-9.815, -2.966) PE: Not calculable^a^ KH: -6.390 (-14.597, 1.817) I^2^ = 16.1%, P = 0.304
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | LDL: metformin vs. combination metformin and rosiglitazone | 7 studies #1: 1006 (34–277) #2: 1149 (71–268) | PL: 0.905 (-1.887, 3.775) DL: 0.905 (-1.887, 3.697) REML: 0.095 (-1.887, 3.697) ML: 0.905 (-1.887, 3.697) PE: 0.905 (-4.920, 1.893) KH: 0.905 (-2.581, 4.391) I^2^ = 0.0%, P = 0.612 | PL: -13.651 (-15.891, -11.342) DL: -13.651 (-15.759, -11.542) REML: -13.651 (-15.759, -11.542) ML: -13.651 (-15.759, -11.542) PE: -13.651 (-88.012, -1.948) KH: -13.651 (-16.283, -11.019) I^2^ = 0%, P = 0.668 | PL: -13.029 (-16.242, -9.463) DL: -13.029 (-16.234, -9.825) REML: -13.029 (-16.234, -9.825) ML: -13.029 (-16.234, -9.825) PE: -13.029 (-73.250, -2.159) KH: -13.029 (-17.030, -9.029) I^2^ = 0%, P = 0.663
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | LDL: metformin vs. combination metformin and sulfonylureas | 6 studies #1: 580 (16–210) #2: 808 (60–213) | PL: -2.719 (-8.339, 2.904) DL: -2.727 (-7.494, 2.041) REML: -2.732 (-7.790, 2.325) ML: -2.719 (-7.213, 1.775) PE: Not calculable^a^ KH: -2.732 (-9.897, 4.432) I^2^ = 9.1%, P = 0.354 | PL: -2.552 (-8.390, 1.539) DL: -2.564 (-6.499, 1.371) REML: -2.930 (-7.434, 1.574) ML: -2.552 (-6.471, 1.367) PE: -2.564 (-31.611, 1.202) KH: -2.930 (-8.837, 2.977) I^2^ = 61.8%, P = 0.022 | PL: -4.212 (-11.003, 0.517) DL: -4.617 (-9.796, 0.562) REML: -4.641 (-9.865, 0.583) ML: -4.212 (-8.764, 0.339) PE: -4.617 (-97.587, 0.248) KH: -4.641 (-11.492, 2.210) I^2^ = 66.2%, P = 0.011
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | LDL: metformin vs. combination metformin and DPP-4 inhibitors | 4 studies #1: 773 (83–245) #2: 1279 86–479) | PL: -0.795 (-6.649, 5.569) DL: -0.639 (-6.663, 5.386) REML: -0.698 (-6.192, 4.797) ML: -0.795 (-5.673, 4.084) PE: Not calculable^a^ KH: -0.698 (-9.619, 8.224) I^2^ = 76.8%, P = 0.005 | PL: 1.739 (-1.432, 5.037) DL: 1.739 (-1.413, 4.890) REML: 1.739 (-1.413, 4.890) ML: 1.739 (-1.413, 4.890) PE: Not calculable^a^ KH: 1.739 (-3.378, 6.855) I^2^ = 0%, P = 0.857 | PL: 1.556 (-3.203, 6.393) DL: 1.553 (-2.625, 5.731) REML: 1.554 (-2.728, 5.836) ML: 1.556 (-2.116, 5.227) PE: Not calculable^a^ KH: 1.554 (-5.399, 8.507) I^2^ = 40.3%, P = 0.170
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | LDL: combination metformin and rosiglitazone vs. combination metformin and sulfonylureas | 4 studies #1: 532 (48– 202) #2: 592 (47– 240) | PL: -2.170 (-5.335, 0.840) DL: -2.170 (-5.163, 0.823) REML: -2.170 (-5.163, 0.823) ML: -2.170 (-5.163, 0.823) PE: Not calculable^a^ KH: -2.170 (-7.029, 2.689) I^2^ = 0.0%, P = 0.724 | PL: 14.825 (9.650, 19.554) DL: 14.768 (10.447, 19.088) REML: 14.748 (10.287, 19.209) ML: 14.825 (10.861, 18.789) PE: Not calculable^a^ KH: 14.748 (7.505, 21.991) I^2^ = 36%, P = 0.196 | PL: 12.736 (7.395, 17.171) DL: 12.577(8.279, 16.876) REML: 12.565 (8.214, 16.915) ML: 12.736 (9.000, 16.472) PE: Not calculable^a^ KH: 12.565 (5.500, 19.629) I^2^ = 39.0%, P = 0.178
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: metformin vs. rosiglitazone | 6 studies #1: 198 (9–117) #2: 213 (14–128) | PL: Does not converge DL: -2.408 (-4.400, -0.416)^b^ REML: -1.995 (-4.393, -0.403)^c^ ML: Does not converge PE: -2.408 (-4.4e+16, 0.016) KH: -1.995 (-5.140, 1.150) I^2^ = 0.0%, P = 0.673 | PL: -0.595 (-1.658, 2.319) DL: -0.052 (-1.877, 1.774) REML: -0.066 (-1.870, 1.738) ML: -0.595 (-1.658, 0.468) PE: -0.052 (-50.905, 0.798) KH: -0.066 (-2.773, 2.641) I^2^ = 42.6%, P = 0.121 | PL: 0.445 (-2.983, 3.832) DL: 0.445 (-2.941, 3.831) REML: 0.445 (-2.941, 3.831) ML: 0.445 (-2.941, 3.831) PE: 0.445 (-5.546, 1.723) KH: 0.445 (-3.996, 4.886) I^2^ = 0%, P = 0.922
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: metformin vs. pioglitazone | 8 studies #1: 736 (16–501) #2: 740 (14–499) | PL: -1.228 (-2.737, 0.170) DL: -1.228 (-2.736, 0.281) REML: -1.157 (-2.761, 0.447) ML: -1.228 (-2.736, 0.281) PE: -1.228 (-47.266, 0.214) KH: -1.157 (-3.261, 0.946) I^2^ = 0.0%, P = 0.745 | PL: -2.780 (-3.461, -0.818) DL: -2.989 (-5.460, -0.519) REML: -2.837 (-4.852, -0.823) ML: -2.780 (-4.683, -0.876) PE: -2.989 (-19.849, -0.191) KH: -2.837 (-5.268, -0.407) I^2^ = 78.9%, P < 0.001 | PL: -3.256 (-6.058, -0.633) DL: -3.387 (-6.749, -0.026) REML: -3.285 (-5.870, -0.700) ML: -3.256 (-5.708, -0.805) PE: -3.387 (-26.620, -0.321) KH: -3.285 (-6.404, -0.166) I^2^ = 87.3%, P < 0.001
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: metformin vs. sulfonylureas | 11 studies #1: 812 (19–210) #2: 858 (18–209) | PL: -0.004 (-1.111, 0.827) DL: 0.019 (-0.787, 0.824) REML: -0.054 (-0.942, 0.835) ML: -0.004 (-0.834, 0.825) PE: 0.019 (-3.215, 0.490) KH: -0.054 (-1.064, 0.957) I^2^ = 0.0%, P = 0. 458 | PL: 0.243 (-0.538, 1.002) DL: 0.243 (-0.505, 0.991) REML: 0.243 (-0.505, 0.991) ML: 0.243 (-0.505, 0.991) PE: 0.243 (-0.342, 0.562) KH: 0.243 (-0.607, 1.094) I^2^ = 0%, P = 0.961 | PL: 0.242 (-0.727, 1.073) DL: 0.232 (-0.608, 1.071) REML: 0.242 (-0.574, 1.057) ML: 0.242 (-0.571, 1.056) PE: 0.232 (-1.730, 0.675) KH: 0.242 (-0.702, 1.185) I^2^ = 3.8%, P = 0.407
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: metformin vs. DPP-4 inhibitors | 3 studies #1: 913 (241–427) #2: 791 (95–440) | PL: 0.711 (-0.271, 1.673) DL: 0.711 (-0.217, 1.639) REML: 0.711 (-0.217, 1.639) ML: 0.711 (-0.217, 1.639) PE: Not calculable^a^ KH: 0.711 (-1.326, 2.748) I^2^ = 0.0%, P = 0. 787 | PL: 1.432 (-0.004, 3.251)^b^ DL: 1.514 (0.132, 2.897) REML: 1.520 (0.117, 2.923) ML: 1.432 (0.288, 2.575) PE: Not calculable^a^ KH: 1.520 (-1.561, 4.600) I^2^ = 34.1%, P = 0.219 | PL: 2.112 (0.705, 3.899)^b^ DL: 2.199 (0.814, 3.584) REML: 2.195 (0.827, 3.562) ML: 2.112 (1.001, 3.222) PE: Not calculable^a^ KH: 2.195 (-0.876, 5.265) I^2^ = 33.9%, P = 0.220
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: metformin vs. combination metformin and rosiglitazone | 7 studies #1: 1069 (34–302) #2: 1248 (71–309) | PL: -0.074 (-1.293, 1.201) DL: -0.072 (-1.139, 0.995) REML: -0.063 (-1.224, 1.097) ML: -0.074 (-1.122, 0.975) PE: -0.072 (-11.071, 0.668) KH: -0.063 (-1.512, 1.386) I^2^ = 10.5%, P = 0. 349 | PL: -3.229 (-4.168, -2.313) DL: -3.230 (-4.134, -2.325) REML: -3.229 (-4.065, -2.394) ML: -3.229 (-4.065, -2.394) PE: -3.230 (-20.158, -0.387) KH: -3.229 (-4.338, -2.120) I^2^ = 11.5%, P = 0.342 | PL: -3.083 (-4.683, -1.541) DL: -3.087 (-4.515, -1.658) REML: -3.088 (-4.544, -1.632) ML: -3.083 (-4.405, -1.762) PE: -3.087(-19.775, -0.138) KH: -3.088 (-4.906, -1.270) I^2^ = 25.5%, P = 0.234
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: metformin vs. combination metformin and sulfonylureas | 5 studies #1: 415 (19–164) #2: 666 74–204) | PL: -0.441 (-2.091, 1.043) DL: -0.441 (-1.867, 0.984) REML: -0.441 (-1.867, 0.984) ML: -0.441 (-1.867, 0.984) PE: Not calculable^a^ KH: -0.441 (-2.461, 1.578) I^2^ = 0.0%, P = 0. 619 | PL: 1.908 (-4.330, 8.218) DL: 1.888 (-2.546, 6.321) REML: 1.922 (-3.791, 7.634) ML: 1.908 (-3.182, 6.998) PE: Not calculable^a^ KH: 1.922 (-6.229, 10.072) I^2^ = 96.0%, P < 0.001 | PL: 1.370 (-5.498, 8.106) DL: 1.361 (-4.395, 7.117) REML: 1.346 (-4.854, 7.545) ML: 1.370 (-4.170, 6.910) PE: Not calculable^a^ KH: 1.346 (-7.444, 10.135) I^2^ = 95.6%, P < 0.001
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: metformin vs. combination metformin and DPP-4 inhibitors | 4 studies #1: 775 (83–245) #2: 1329 (86–528) | PL: -0.596 (-1.529, 0.354) DL: -0.596 (-1.527, 0.334) REML: -0.596 (-1.527, 0.334) ML: -0.596 (-1.527, 0.334) PE: Not calculable^a^ KH: -0.596 (-2.107, 0.914) I^2^ = 0.0%, P = 0. 967 | PL: 0.210 (-0.954, 1.316) DL: 0.210 (-0.861, 1.281) REML: 0.210 (-0.861, 1.281) ML: 0.210 (-0.861, 1.281) PE: Not calculable^a^ KH: 0.210 (-1.528, 1.948) I^2^ = 0%, P = 0.644 | PL: -0.324 (-1.626, 0.885) DL: -0.324 (-1.420, 0.773) REML: -0.324 (-1.420, 0.773) ML: -0.324 (-1.420, 0.773) PE: Not calculable^a^ KH: -0.324 (-2.104, 1.457) I^2^ = 0%, P = 0.494
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: pioglitazone vs. sulfonylurea | 6 studies #1: 304 (17–91) #2: 311 (18–109) | PL: 1.375 (-0.020, 2.695) DL: 1.375 (0.074, 2.675)^b^ REML: 1.375 (0.074, 2.675)^c^ ML: 1.375 (0.074, 2.675)^c^ PE: 1.375 (-0.783, 2.297) KH: 1.375 (-0.331, 3.081) I^2^ = 0.0%, P = 0. 706 | PL: 5.295 (3.480, 6.964) DL: 5.278 (3.472, 7.084) REML: 5.306 (3.786, 6.825) ML: 5.295 (4.068, 6.522) PE: 5.278 (-0.000, 7.4e+14) KH: 5.306 (2.896, 7.716) I^2^ = 43.3%, P = 0.117 | PL: 6.369 (3.528, 8.853) DL: 6.325 (4.021, 8.630) REML: 6.298 (3.864, 8.733) ML: 6.369 (4.252, 8.486) PE: Does not converge KH: 6.298 (3.059, 9.538) I^2^ = 60.5%, P = 0.027
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: sulfonylureas vs. meglitinides | 6 studies #1: 529 (18–182) #2: 885 (16–362) | PL: 0.699 (-1.148, 2.312) DL: 0.699 (-0.876, 2.274) REML: 0.699 (-0.876, 2.274) ML: 0.699 (-0.876, 2.274) PE: Not calculable^a^ KH: 0.699 (-2.759, 4.156) I^2^ = 0.0%, P = 0. 750 | PL: 0.018 (-0.179, 0.133) DL: -0.457 (-1.566, 0.653) REML: -0.584 (-1.955, 0.787) ML: 0.018 (-0.047, 0.083) PE: Not calculable^a^ KH: -0.584 (-2.526, 1.358) I^2^ = 53.5%, P = 0.072 | PL: 0.029 (-0.120, 0.152) DL: -0.011 (-0.453, 0.431) REML: 0.029 (-0.036, 0.094) ML: 0.029 (-0.036, 0.094) PE: Not calculable^a^ KH: 0.029 (-0.067, 0.125) I^2^ = 8.1%, P = 0.360
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | HDL: combination metformin and rosiglitazone vs. combination metformin and sulfonylureas | 4 studies #1: 577 (48–210) #2: 613 (47–240) | PL: -0.539 (-1.836, 0.696) DL: -0.552 (-1.681, 0.577) REML: -0.552 (-1.679, 0.576) ML: -0.539 (-1.513, 0.436) PE: Not calculable^a^ KH: -0.552 (-2.388, 1.284) I^2^ = 35.0%, P = 0. 202 | PL: 3.048 (1.714, 4.862) DL: 3.155 (1.776, 4.535) REML: 3.160 (1.767, 4.552) ML: 3.048 (1.909, 4.188) PE: Not calculable^a^ KH: 3.160 (0.856, 5.464) I^2^ = 25.8%, P = 0.257 | PL: 2.490 (0.968, 4.439) DL: 2.576 (1.064, 4.087) REML: 2.582 (1.049, 4.116) ML: 2.490 (1.207, 3.774) PE: Not calculable^a^ KH: 2.582 (0.025, 5.139) I^2^ = 61.5%, P = 0.051
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Triglycerides: metformin vs. rosiglitazone | 6 studies #1: 198 (9–117) #2: 213 (14–128) | PL: Does not converge DL: -9.516 (-37.750, 18.717) REML: -9.657 (-37.090, 17.777) ML: -10.011 (-34.080, 14.058) PE: -9.516 (-1.4e+17, 10.651) KH: -9.657 (-47.354, 28.041) I^2^ = 65.9%, P = 0. 012 | PL: does not converge DL: -10.005 (-43.660, 23.651) REML: -9.362 (-45.739, 27.015) ML: -10.051 (-43.533, 23.430) PE: -10.005 (-190.295, 12.301) KH: -9.362 (-57.072, 38.348) I^2^ = 89.2%, P < 0.001 | PL: -9.166 (-22.621, 5.619) DL: -9.166 (-21.899, 3.568) REML: -9.166 (-21.899, 3.568) ML: -9.166 (-21.899, 3.568) PE: -9.166 (-2.1e+17, 2.401) KH: -9.166 (-25.866, 7.535) I^2^ = 0.0%, P = 0.542
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Triglycerides: comparing metformin vs. pioglitazone | 8 studies #1: 736 (16–501) #2: 740 (14–499) | PL: Does not converge DL: -17.691 (-44.411, 9.029) REML: -18.430 (-46.652, 9.792) ML: -5.445 (-17.344, 6.454) PE: -17.691 (-147.142, 0.280) KH: -18.430 (-56.346, 19.486) I^2^ = 51.9%, P = 0. 052 | PL: 4.561 (-7.327, 16.511) DL: 4.561 (-7.321, 16.442) REML: 4.561 (-7.321, 16.442) ML: 4.561 (-7.321, 16.442) PE: 4.561 (0.821, 32.654) KH: 4.561 (-9.774, 18.895) I^2^ = 0.0%, P = 0.820 | PL: 2.015 (-8.812, 15.063) DL: 2.015 (-8.523, 12.553) REML: 2.015 (-8.523, 12.553) ML: 2.015 (-8.523, 12.553) PE : 2.015 (-4.551, 9.978) KH: 2.015 (-10.699, 14.728) I^2^ = 0.0%, P = 0.981
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Triglycerides: metformin vs. sulfonylureas | 11 studies #1: 812 (19–210) #2: 858 (18–209) | PL: 17.186 (-2.503, 23.406) DL: 17.186 (10.965, 23.406)^b^ REML: 11.553 (-0.041, 23.147) ML: 17.186 (10.965, 23.406)^c^ PE: 17.186 (-18.623, 22.103) KH: 11.553 (-1.628, 24.733) I^2^ = 0.0%, P = 0. 500 | PL: -17.217 (-28.683, -4.876)^b^ DL: -17.217 (-28.684, -5.750)^b^ REML: -17.217 (-28.684, -5.750)^c^ ML: -17.217 (-28.684, -5.750)^c^ PE: -17.217 (-94.192, -0.855) KH: -17.217 (-30.253, -4.181)^c^ I^2^ = 0.0%, P = 0.669 | PL: -5.847 (-23.606, 10.612)^b^ DL: -6.444 (-24.536, 11.648)^b^ REML: -6.120 (-22.472, 10.232)^c^ ML: -5.847 (-21.399, 9.706)^c^ PE: -6.444 (-84.395, 5.507) KH: -6.120 (-24.709, 12.470)^c^ I^2^ = 67.9%, P = 0.001
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Triglycerides: metformin vs. DPP-4 Inhibitors | 3 studies #1: 940 (241–427) #2: 820 (96–441) | PL: 7.335 (-5.673, 20.817) DL: 7.335 (-4.245, 18.916) REML: 7.335 (-4.245, 18.916) ML: 7.335 (-4.245, 18.916) PE: Not calculable^a^ KH: 7.335 (-18.086, 32.757) I^2^ = 0.0%, P = 0. 616 | PL: 3.047 (-11.286, 18.285) DL: 3.047 (-10.969, 17.063) REML: 3.047 (-10.969, 17.063) ML: 3.047 (-10.969, 17.063) PE: Not calculable^a^ KH: 3.047 (-27.722, 33.815) I^2^ = 0.0%, P = 0.845 | PL: 9.797 (-5.000, 28.534) DL: 9.797 (-4.105, 23.699) REML: 9.797 (-4.105, 23.699) ML: 9.797 (-4.105, 23.699) PE: Not calculable^a^ KH: 9.797 (-20.722, 40.316) I^2^ = 0%, P = 0.419
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Triglycerides: metformin vs. combination metformin and rosiglitazone | 7 studies #1: 1035 (34–266) #2: 1210 (71–271) | PL: -3.495 (-12.625, 6.168) DL: -3.400 (-13.238, 6.437) REML: -3.495 (-11.744, 4.754) ML: -3.495 (-11.744, 4.754) PE: -3.400 (-147.146, 2.542) KH: -3.495 (-15.169, 8.179) I^2^ = 22.2%, P = 0. 260 | PL: does not converge DL: -4.990 (-18.190, 8.210) REML: -4.966 (-17.227, 7.295) ML: -4.824 (-16.079, 6.430) PE: -4.990 (-160.681, 3.206) KH: -4.966 (-20.274, 10.342) I^2^ = 67.8%, P = 0.005 | PL: -8.487 (-22.309, 9.286) DL: -7.806 (-22.264, 6.651) REML: -7.840 (-22.219, 6.538) ML: -8.487 (-21.426, 4.452) PE: -7.806 (-131.261, 4.355) KH: -7.840 (-26.855, 11.175) I^2^ = 60.3%, P = 0.019
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Triglycerides: metformin vs. combination metformin and sulfonylureas | 6 studies #1: 625 (19–210) #2: 879 (74–213) | PL: 0.700 (-18.082, 18.057) DL: 0.700 (-16.590, 17.990) REML: 0.700 (-16.590, 17.990) ML: 0.700 (-16,590, 17.990) PE: 0.700 (-82.625, 7.379) KH: 0.700 (-21.977, 23.376) I^2^ = 0.0%, P = 0. 850 | PL: 9.941 (-2.404, 22.002) DL: 9.941 (-2.084, 21.967) REML: 9.941 (-2.084, 21.967) ML: 9.941 (-2.084, 21.967) PE: 9.941 (-34.244, 11.815) KH: 9.941 (-5.831, 25.713) I^2^ = 0.0%, P = 0.826 | PL: does not converge DL: 6.214 (-12.041, 24.470) REML: 6.186 (-12.214, 24.587) ML: 6.637 (-9.710, 22.985) PE: 6.214 (-1.1e+17, 16.196) KH: 6.186 (-18.328, 30.700) I^2^ = 47.1%, P = 0.092
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Triglycerides: metformin vs. combination metformin and DPP-4 inhibitors | 4 studies #1: 802 (83–272) #2: 1331 (86–528) | PL: 2.980 (-7.643, 13.705) DL: 2.980 (-6.932, 12.891) REML: 2.980 (-6.932, 12.891) ML: 2.980 (-6.932, 12.891) PE: Not calculable^a^ KH: 2.980 (-13.114, 19.073) I^2^ = 0.0%, P = 0. 683 | PL: 27.447 (15.424, 39.419) DL: 27.447 (15.611, 39.283) REML: 27.447 (15.611, 39.283) ML: 27.447 (15.611, 39.283) PE: Not calculable^a^ KH: 27.447 (8.228, 46.666) I^2^ = 0.0%, P = 0.904 | PL: 30.498 (17.956, 42.971) DL: 30.498 (18.169, 42.827) REML: 30.498 (18.169, 42.827) ML: 30.498 (18.169, 42.827) PE: Not calculable^a^ KH: 30.498 (10.479, 50.517) I^2^ = 0.0%, P = 0.905
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Triglycerides: pioglitazone vs. sulfonylureas | 6 studies #1: 304 (17–91) #2: 311 (18–109) | PL: -2.571 (-18.550, 16.510) DL: -2.349 (-18.616, 13.919) REML: -2.571 (-17.931, 12.789) ML: -2.571 (-17.931, 12.789) PE: -2.349 (-324.811, 7.121) KH: -2.571 (-23.511, 18.369) I^2^ = 7.4%, P = 0. 369 | PL: -28.553 (-45.047, -13.327) DL: -28.553 (-42.577, -14.529) REML: -28.553 (-42.577, -14.529) ML: -28.553 (-42.577, -14.529) PE: -28.553 (-5.1e+17, 0.000) KH: -28.553 (-46.946, -10.159) I^2^ = 0.0%, P = 0.463 | PL: does not converge DL: -28.042 (-46.283, -9.801) REML: -29.172 (-44.610, -13.734) ML: -30.302 (-43.159, -17.445) PE: -28.042 (-5.6e+17, 2.996) KH: -29.172 (-53.547, -4.797) I^2^ = 42.4%, P = 0.122
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Triglycerides: sulfonylureas vs. meglitinides | 4 studies #1: 320 (18–182) #2: 580 (16–362) | PL: Does not converge DL: 11.258 (-5.843, 28.359) REML: 11.258 (-5.843, 28.359) ML: 13.733 (2.823, 24.643) PE: Not calculable^a^ KH: 11.258 (-99.605, 122.121) I^2^ = 39.7%, P = 0. 198 | PL: 1.095 (-11.167, 11.568) DL: 1.095 (-9.197, 11.388) REML: 1.095 (-9.197, 11.388) ML: 1.095 (-9.197, 11.388) PE: Not calculable^a^ KH: 1.095 (-15.617, 17.807) I^2^ = 0.0%, P = 0.898 | PL: does not converge DL: 7.724 (-7.293, 22.742) REML: 7.086 (-8.897, 23.069) ML: 9.169 (-4.029, 22.366) PE: Not calculable^a^ KH: 7.086 (-18.866, 33.039) I^2^ = 32.2%, P = 0.219
Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update of the 2007 Report 19 | Triglycerides: combination metformin and rosiglitazone vs. combination metformin and sulfonylureas | 4 studies #1: 576 (48–210), #2: 611 (47–240) | PL: 7.028 (-2.966, 16.345) DL: 6.851 (-2.177, 15.878) REML: 6.930 (-1.204, 15.065) ML: 7.028 (-0.271, 14.327) PE: Not calculable^a^ KH: 6.930 (-7.690, 21.550) I^2^ = 27.9%, P = 0. 245 | PL: does not converge DL: 6.739 (-15.969, 29.448) REML: 6.303 (-13.188, 25.795) ML: 5.833 (-11.500, 23.165) PE: Not calculable^a^ KH: 6.303 (-25.346, 37.953) I^2^ = 83.9%, P < 0.001 | PL: does not converge DL: 13.608 (-9.217, 36.434) REML: 13.499 (-7.695, 34.692) ML: 13.242 (-5.156, 31.639) PE: Not calculable^a^ KH: 13.499 (-20.913, 47.911) I^2^ = 91.8%, P < 0.001

a Not calculable as there are fewer than six studies.

b Significant baseline difference or discrepancy in conclusion using DL or PL methods.

c Significant baseline difference or discrepancy in conclusion using REML, ML, PE or KH methods.

d Only one study.

e Hartung-Knapp-Sidik-Jonkman method as implemented in [underlined: IntHout] et al. 2015^28^ was used. Otherwise, the KH estimate was obtained using Stata command metareg.

CI = confidence interval; CPAP = continuous positive airway pressure; DL = DerSimonian-Laird random-effects method; DPP-4 = Dipeptidyl peptidase-4; HbA1c = hemoglobin A1c/glycated hemoglobin; HDL = high-density lipoprotein; LDL = low-density lipoprotein; MADRS = Montgomery-Asberg Depression Rating Scale; ML = maximum likelihood method; PE = permutations method; PL = profile likelihood method; REML = restricted maximum likelihood method.