# Comparison of Combined Mean Differences Using Change Score and Endpoints (Treatment Versus Control)

Comparative Effectiveness Review | Outcome: Comparison (Group #1 vs. Group #2) | Number of Studies (N) Group #1 and Group #2 Total Sample Size (Min–Max) | Baseline Difference (95% CI) | Difference in Change Score (95% CI) | Difference in Endpoint Score (95% CI) | Percentage Difference in Combined Estimates
Pain Management Interventions for Hip Fracture 15 | Acute pain: skin traction vs. no traction | 13 studies #1: 568 (30–166) #2: 662 (34–151) | PL: -0.300 (-0.812, 0.260) DL: -0.281 (-0.843, 0.280) REML: -0.293 (-0.802, 0.216) ML: -0.300 (-0.782, 0.181 PE: -0.281 (-2.097, 0.062) KH: -0.293 (-0.907, 0.321) I^2^ = 77.2%, P < 0.001 | PL: 0.432 (-0.137, 0.997) DL: 0.431 (-0.125, 0.987) REML: 0.431 (-0.106, 0.968) ML: 0.432 (-0.073, 0.938) PE: 0.431 (-0.411, 0.743) KH: 0.431 (-0.217, 1.08) I^2^ = 76.5%, P < 0.001 | PL: 0.115 (-0.332, 0.617) DL: 0.122 (-0.316, 0.561) REML: 0.123 (-0.318, 0.565) ML: 0.115 (-0.290, 0.519) PE: 0.122 (-1.211, 0.344) KH: 0.123 (-0.427, 0.673) I^2^ = 63.2%, P = 0.008 | PL: 73% DL: 72% REML: 71% ML: 73% PE: 72% KH:71%
Diagnosis and Treatment of Obstructive Sleep Apnea in Adults 16 | Apnea-Hypopnea Index: CPAP vs. control | 6 studies #1: 177 (12–66) #2: 159 (12–59) | PL: 2.208 (-3.442, 9.009) DL: 2.532 (-2.798, 7.862) REML: 2.592 (-3.029, 8.212) ML: 2.208 (-2.134, 6.550) PE: 2.532 (-7.179, 9.793) KH: 2.592 (-5.711, 10.895) I^2^ = 64.7%, P = 0.015 | PL: -27.022 (-41.194, -13.631) DL: -27.051 (-38.909, -15.193) REML: -27.161 (-39.922, -14.401) ML: -27.022 (-38.680, -15.365) PE: -27.051 (-157.441, 0.000) KH: -27.161 (-43.898, -10.425) I^2^ = 93.3%, P < 0.001 | PL: -24.176 (-36.050, -13.153) DL: -24.134 (-33.599, -14.669) REML: -24.325 (-34.925, -13.724) ML: -24.176 (-33.865, -14.488) PE: -24.134 (-136.260, -0.000) KH: -24.325 (-38.227, -10.422) I^2^ = 91.9%, P < 0.001 | PL: -11% DL: -11% REML: -10% ML: -11% PE: -11% KH: -10%
Diagnosis and Treatment of Obstructive Sleep Apnea in Adults 16 | Epworth Sleepiness Scale: CPAP vs. control | 7 studies #1: 448 (19–178) #2: 398 (21–181) | PL: -0.015 (-0.523, 0.494) DL: -0.015 (-0.435, 0.406) REML: -0.015, (-0.435, 0.406) ML: -0.015 ( -0.435, 0.406) PE: -0.015 (-2.242, 0.336) KH: -0.015 (-0.540, 0.510) I^2^ = 0%, P = 0.805 | PL: -2.684 (-4.311, -1.169) DL: -2.714 (-4.274, -1.155) REML: -2.702 (-4.179, -1.225) ML: -2.684 (-4.064, -1.304) PE: -2.714 (-18.518, -0.186) KH: -2.702 (-4.546, -0.858) I^2^ = 84.3%, P < 0.001 | PL: -2.325 (-3.645, -1.220) DL: -2.371 -3.415, -1.327) REML: -2.387 (-3.458, -1.317) ML: -2.325 (-3.305, -1.346) PE: -2.371 (-18.241, -0.161) KH: -2.387 (-3.724, -1.051) I^2^ = 54.2%, P = 0.042 | PL: -13% DL: -12% REML: -12% ML: -13% PE: -13% KH: -12%
Diagnosis and Treatment of Obstructive Sleep Apnea in Adults 16 | Apnea-Hypopnea Index: CPAP vs. sham CPAP | 8 studies #1: 163 (15–27) #2: 149 (10–29) | PL: 7.161 (1.241, 13.088)^a^ DL: 7.161 (1.260, 13.063)^a^ REML: 7.161 (1.260, 13.063) ML: 7.161 (1.260, 13.063) PE: 7.161 (0.780, 9.416) KH: 7.161 (0.041, 14.281) I^2^ = 0%, P = 0.920 | PL: -45.634 (-58.285, -34.180) DL: -45.891 (-57.534, -34.249) REML: -45.826 (-57.209, -34.444) ML: -45.634 (-56.334, -34.933) PE: -45.891 (-321.166, -7.516) KH: -45.826 (-59.559, -32.094) I^2^ = 70.9%, P = 0.001 | PL: -40.495 (-52.287, -29.403) DL: -40.690 (-52.073, -29.307) REML: -40.608 (-51.424, -29.791) ML: -40.495 (-50.659, -30.330) PE: -40.690 (-280.617, -6.796) KH: -40.608 (-53.657, -27.558) I^2^ = 82.4%, P < 0.001 | PL: -11% DL: -11% REML: -11% ML: -11% PE: -11% KH: -11%
Diagnosis and Treatment of Obstructive Sleep Apnea in Adults 16 | Epworth Sleepiness Scale: CPAP vs. sham CPAP | 11 studies #1: 293 (16–52) #2: 291 16–49) | PL: 0.309 (-0.263, 0.876) DL: 0.309 (-0.258, 0.876) REML: 0.309 (-0.258, 0.876) ML: 0.309 (-0.258, 0.876) PE: 0.309 (-0.192, 0.644) KH: 0.309 (-0.336, 0.954) I^2^ = 0%, P = 0.920 | PL: -2.684 (-4.345, -1.033) DL: -2.688 (-4.399, -0.977) REML: -2.686 (-4.277, -1.095) ML: -2.684 (-4.206, -1.162) PE: -2.688 (-10.240, -0.329) KH: -2.686 (-4.495, -0.877) I^2^ = 83.4%, P < 0.001 | PL: -2.555 (-4.197, -0.918) DL: -2.556 (-4.209, -0.904) REML: -2.555 (-4.130, -0.980) ML: -2.555 (-4.061, -1.048) PE: -2.556 (-9.499, -0.309) KH: -2.555 (-4.346, -0.765) I^2^ = 82.2%, P < 0.001 | DL: -5% PL: -5% REML: -5% ML: -5% PE: -5% KH: -5%
Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults 17 | Depressive severity: rTMS vs. sham (condition = Tier 1, MDD) | 8 studies #1: 116 (7–32) #2: 102 (5–31) | PL: 0.638 (-0.530, 2.671) DL: 0.638 (-0.460, 1.736) REML: 0.638 (-0.460, 1.736) ML: 0.638 (-0.460, 1.736) PE: 0.638 (0.110, 3.733) KH: 0.638 (-0.687, 1.963) I^2^ = 0%, P = 0.520 | PL: -5.442 (-7.792, -2.672)^a^ DL: -5.394 (-7.764, -3.025)^a^ REML: -5.372 (-7.787, -2.958)^b^ ML: -5.442 (-7.726, -3.158) PE: -5.394 (-33.449, -0.607) KH: -5.372 (-8.285, -2.459)^b^ I^2^ = 43.9%, P = 0.086 | PL: -3.068 (-6.171, 0.371)^a^ DL: -2.898 (-6.508, 0.711)^a^ REML: -3.023 (-6.114, 0.068)^b^ ML: -3.068 (-5.990, -0.146) PE: -2.898 (-23.845, 0.351) KH: -3.023 (-6.752, 0.706)^b^ I^2^ = 79.2%, P < 0.001 | PL: -44% DL: -45% REML: -44% ML: -44% PE: -46% KH: -44%
Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults 17 | Depressive severity: rTMS vs. sham (condition = Tier 1) | 11 studies #1: 197 (7–36) #2: 149 (5–31) | PL: 0.680 (-0.374, 2.276) DL: 0.680 (-0.276, 1.636) REML: 0.680 (-0.276, 1.636) ML: 0.680 (-0.276, 1.636) PE: 0.680 (0.039 1.849) KH: 0.680 (-0.407, 1.767) I^2^ = 0%, P = 0.452 | PL: -5.690 (-7.813, -3.478) DL: -5.672 (-7.784, -3.561) REML: -5.676 (-7.760, -3.593) ML: -5.690 (-7.684, -3.696 PE: -5.672 (-22.270, -1.136) KH: -5.676 (-8.045, -3.308) I^2^ = 54.4%, P = 0.015 | PL: -3.906 (-6.284, -1.401) DL: -3.841 (-6.482, -1.199) REML: -3.891 (-6.236, -1.547) ML: -3.906 (-6.156, -1.657) PE: -3.841 (-16.307, -0.396) KH: -3.891 (-6.557, -1.226) I^2^ = 73.6%, P < 0.001 | PL: -31% DL: -32% REML: -31% ML: -3% PE: -32% KH: -31%
Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults 17 | Depressive severity: rTMS vs. sham (condition = Tier 1 & Tier 2, MDD) | 12 studies #1: 374 (7–155) #2: 364 (5–146) | PL: -0.013 (-0.595, 0.764) DL: -0.013 (-0.569, 0.544) REML: -0.013 (-0.569, 0.544) ML: -0.013 (-0.569, 0.544) PE: -0.013 (-2.420, 0.169) KH: -0.013 (-0.637, 0.612) I^2^ = 0%, P = 0.688 | PL: -4.719 (-7.097, -2.319) DL: -4.714 (-7.126, -2.301) REML: -4.717 (-7.024, -2.410) ML: -4.719 (-6.937, -2.501) PE: -4.714 (-17.932, -0.890) KH: -4.717 (-7.307, -2.126) I^2^ = 80.4%, P < 0.001 | PL: -3.441 (-5.943, -0.802) DL: -3.436 (-5.83, -1.041) REML: -3.424 (-5.893, -0.955) ML: -3.441 (-5.805, -1.077) PE: -3.436 (-14.074, -0.313) KH: -3.424 (-6.197, -0.651) I^2^ = 79.3%, P < 0.001 | PL: -27% DL: -27% REML: -27% ML: -27% PE: -27% KH: -27%
Screening, Behavioral Counseling, and Referral in Primary Care to Reduce Alcohol Misuse 20 | Drinks/week: BCI vs. control (adults, 6 months) | 11 studies #1: 1547 (39-353) #2: 1556 (32-376) | PL: 0.613 (-0.247, 1.606) DL: 0.613 (-0.229, 1.456) REML: 0.613 (-0.229, 1.456) ML: 0.613 (-0.229, 1.456) PE: 0.613 (-0.312, 1.561) KH: 0.613 (-0.345, 1.571) I^2^ = 0%, P = 0.490 | PL: -3.121 (-4.255, -2.310) DL: -3.228 (-4.214, -2.242) REML: -3.121 (-3.931, -2.310) ML: -3.121 (-3.931, -2.310) PE: -3.228 (-17.773, -0.355) KH: -3.121 (-4.114, -2.127) I^2^ =13.9%, P = 0.311 | PL: -2.504 (-4.037, -1.210) DL: -2.593 (-4.063, -1.123) REML: -2.561 (-3.839, -1.284) ML: -2.504 (-3.466, -1.542) PE: -2.593 (-13.018, -0.138) KH: -2.561 (-4.322, -0.800) I^2^ =46.3%, P = 0.046 | PL: -20% DL: -20% REML: -18% ML: -20% PE: -20% KH: -18%
Screening, Behavioral Counseling, and Referral in Primary Care to Reduce Alcohol Misuse 20 | Drinks/week: BCI vs. control (adults, 12 months) | 13 studies #1: 2088 (33-371) #2: 2012 (39-381) | PL: 0.455 (-0.403, 1.282) DL: 0.455 (-0.364, 1.274) REML: 0.455 (-0.364, 1.274) ML: 0.455 (-0.364, 1.274) PE: 0.455 (-0.903, 1.079) KH: 0.455 (-0.455, 1.365) I^2^ = 0%, P = 0.649 | PL: -3.700 (-4.641, -2.805) DL: -3.718 (-4.760, -2.677) REML: -3.700 (-4.529, -2.871) ML: -3.700 (-4.529, -2.871) PE: -3.718 (-15.177, -0.711) KH: -3.700 (-4.711, -2.689) I^2^ =16.9%, P = 0.274 | PL: -2.920 (-4.912, -0.800) DL: -2.936 (-4.601, -1.272) REML: -2.900 (-4.849, -0.951) ML: -2.920 (-4.718 -1.121) PE: -2.936 (-12.488, -0.215) KH: -2.900 (-5.182, -0.618) I^2^ =57.2%, P = 0.005 | PL: -21% DL: -21% REML: -22% ML: -21% PE: -21% KH: -22%

a Significant baseline difference or discrepancy in conclusion using DL or PL methods.

b Significant baseline difference or discrepancy in conclusion using REML, ML, PE or KH methods.

BCI = behavioral counseling intervention; CI = confidence interval; CPAP = continuous positive airway pressure; DL = DerSimonian-Laird random-effects method; MDD = major depressive disorder; ML = maximum likelihood method; PE = permutations method; PL = profile likelihood method; REML = restricted maximum likelihood method; rTMS = repetitive transcranial magnetic stimulation.